# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-57, Atlanta, Georgia 30333.

## 1,2,4-Trichlorobenzene Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,4-Trichlorobenzene
CAS Number: | 120-82-1
Date: | May 2014
Profile Status: | Final Post-Public Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 21
Species: | Rat

[underlined: Minimal Risk Level]: 0.1 [x] mg/kg/day [ ] ppm

[underlined: Reference]: CMA. 1989. A three month dietary range-finding study of 1,2,4-trichlorobenzene in rats final report with letter dated 2/2/89 from Chemical Manufacturers Association. Chemical Manufacturers Association. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. EPA Document No. 40-98201006. OTS0523023.

[underlined: Experimental design]: Groups of Fisher-344 rats (10/sex/group) were fed a diet containing 0, 200, 600, or 1,800 ppm 1,2,4-trichlorobenzene for 14 weeks; this diet provided doses of 0, 14.6, 45.6, or 133.7 mg/kg/day for males and 0, 17, 52.5, or 150.6 mg/kg/day for females. These doses were calculated by dividing the sum of the weekly doses provided by the investigators by 14 weeks. End points monitored included clinical signs (daily), physical examination (weekly), ophthalmology (initiation and termination), body weight and food consumption (weekly), hematology and clinical chemistry (termination), gross necropsy (all rats at termination), selected organ weights, and histopathology of all major organs and tissues of the control and high-dose group and liver and kidney of the low- and mid-dose groups.

[underlined: Effect noted in study and corresponding doses]: Treatment with 1,2,4-trichlorobenzene did not affect survival rate. Clinical signs were limited to chromodacryorrhea and lacrimation, which occurred more frequently in treated groups, but without dose-response. The test for ocular abnormalities did not reveal compound-related effects. Administration of 1,2,4-trichlorobenzene did not significantly affect body weight or weight gain. Food consumption was significantly higher in the mid- and high-dose groups than in controls. Hematological alterations consisted of decreased mean erythrocyte count (5%), hemoglobin (7%), and hematocrit (5%) in males dosed with 133.7 mg/kg/day and decreased hemoglobin (4%) and hematocrit (4%) in females dosed with 150.6 mg/kg/day. These changes are within the normal range and are not considered biologically significant. Platelets were significantly increased (16%) in males dosed with 133.7 mg/kg/day; the toxicological significance of this finding is unclear. Significant clinical chemistry changes included elevated BUN in high-dose males (12%) and females (20%), elevated total protein, albumin, and calcium in high-dose males, and lower serum AST activity in males dosed with 45.6 mg/kg/day (22%) and 133.7 mg/kg/day (28%). The elevated BUN was consistent with microscopic alterations in kidneys from male rats. The clinical significance of the alterations in protein and calcium were unclear and the lower transaminase activity was not considered of biological significance. Significant changes in organ weight included dose-related increases in absolute and relative liver weight in all male groups and in mid- and high-dose females, and increased absolute and relative kidneys weight and absolute testes weight in males dosed with 133.7 mg/kg/day. No compound-related gross lesions were observed. Histopathological alterations were limited to the kidneys and liver. Kidney lesions were evident in males dosed with 45.6 and 133.7 mg/kg/day and consisted of dilated tubules, granular casts, hyaline droplets, interstitial nephritis, and papillary mineral deposition. In the liver, centrilobular hepatocyte hypertrophy occurred in males dosed with 45.6 and 133.7 mg/kg/day (0/10, 0/10, 5/10, and 10/10) and in females dosed with 150.6 mg/kg/day (0/10, 0/10, 0/10, and 10/10). Hepatocyte hypertrophy was the probable cause of the increases in liver weight. Liver changes were more prominent in males than in females.

Data for renal effects in male rats were not considered for MRL derivation due to the strong possibility that this may be a unique response of the male rat and not relevant for quantitative risk assessment (EPA 1991). Specific indications that this may be the case include the increased incidences of hyaline droplets, granular casts, and tubule dilation, and the fact that none of these lesions occurred in female rats. In addition, since there is not enough evidence to dissociate the interstitial nephritis from the male-specific nephropathy, interstitial nephritis was also not considered for modeling. In support of this position is the fact that interstitial nephritis did not occur in female rats.

[underlined: Dose and end point used for MRL derivation]: BMDL_10_ of 14.35 mg/kg/day for centrilobular hepatocyte hypertrophy in male rats.

[ ] NOAEL [ ] LOAEL [ X ] BMDL_10_

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Yes, done by the investigators.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: The liver was also a target in an additional 3-month study in rats and in a 13-week study in mice. The study in Sprague-Dawley rats evaluated hematology, clinical chemistry and histopathology of the major organ and tissues, and reported histological alterations in the liver, kidneys, and thyroid in the various dose groups (doses ranged from 0.07 to 82 mg/kg/day in males and from 0.11 to 101 mg/kg/day in females) (Côté et al. 1988). However, the investigators provided only a qualitative description of the results regarding histopathology. In that study, high-dose males showed increases of 13 and 20% in absolute and relative liver weight, respectively, and of 31 and 36% in absolute and relative kidneys weight, respectively. Hematology and clinical chemistry tests were unremarkable. In the 13-week study in mice, groups of B6C3F_1_ mice (10/sex/group) were administered a diet that provided doses of 0, 67, 850, or 1,222 mg/kg/day to males and 0, 86, 1,183, or 1,345 mg/kg/day to females (Hiles 1989). End points monitored included clinical signs twice daily and body weight and food consumption weekly. Hematology and clinical chemistry tests were conducted at initiation and during week 14. At termination, gross necropsy was conducted, selected organs were weighed, and selected tissues were examined microscopically. The lungs, liver, and kidneys from all groups were examined; other organs from only the control and high-dose group were examined. Final body weight was significantly reduced in high-dose males (9%) and females (8.3%). Cumulative body weight gain was significantly reduced in low-dose males (27%), high-dose males (40%) and high-dose females (33%); these changes were associated with significant reductions in food consumption throughout the study. Ophthalmologic examinations were conducted at initiation and termination. Significant, treatment-related alterations occurred only in the liver from males dosed with ≥850 mg/kg/day and females dosed with ≥1,183 mg/kg/day; the respective NOAELs were 67 and 86 mg/kg/day. The lesions consisted of hepatocellular cytomegaly with karyomegaly and hepatocellular atrophy and degeneration. The incidences in males and females were 0/10, 0/10, 10/10, and 10/10 and 0/9, 0/10, 10/10, and 9/9, respectively (one control female and one high-dose female were accidentally killed during the study).

[underlined: Agency Contacts (Chemical Managers)]: Obaid Faroon, D.V.M., Ph.D.

#### BENCHMARK MODELING OF HEPATOCELLULAR HYPERTROPHY IN MALE RATS

Models in the EPA Benchmark Software (BMDS version 2.1) were fit to the incidence data for centrilobular hepatocyte hypertrophy in male rats from the CMA (1989) study. Only incidences in males were modeled (0/10, 0/10, 5/10, 10/10); incidences in females (0/10, 0/10, 0/10, 10/10) were judged not amenable for benchmark analysis. A BMR of 10% was selected in the absence of data that would support a lower BMR. In accordance with EPA (2000a) guidance, BMDs and BMDLs associated with an extra risk of 10% are calculated for all models. Adequate model fit is judged by three criteria: goodness-of-fit (p>0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined benchmark response (BMR). Among all of the models providing adequate fit to the data, the BMDL from the model with the lowest AIC is chosen. The Gamma model was selected for MRL derivation (Table A-1).

Table A-1 Model Predictions for the Incidence of Centrilobular Hepatocyte Hypertrophy in Male Rats Exposed to 1,2,4-Trichlorobenzene

Model | χ^2^ Goodness of fit p-value^a^ | AIC | BMD_10_ (mg/kg/day) | BMDL^10^ (mg/kg/day)
Gamma ^b^ ^,^ ^c^ | 1.00 | 15.86 | 33.09 | 14.35
Logistic | 1.00 | 17.86 | 41.94 | 18.95
Log-Logistic^d^ | 1.00 | 17.86 | 40.29 | 16.74
Log-Probit^d^ | 1.00 | 17.86 | 35.74 | 16.04
Multistage (1-degree)^e^ | 0.26 | 23.05 | 6.43 | 4.04
Multistage (2-degree) | 0.85 | 17.29 | 18.59 | 8.90
Multistage (3-degree) | 0.97 | 16.31 | 24.71 | 10.07
Probit | 1.00 | 17.86 | 38.66 | 17.28
Weibull^b^ | 1.00 | 17.86 | 37.74 | 13.40
Quantal-Linear | 0.26 | 23.05 | 6.43 | 4.04

a Values <0.10 fail to meet conventional goodness-of-fit criteria.

b Power restricted to ≥1.

c Best-fitting model. Among models with adequate fit, the model with the lowest AIC was selected (Gamma).

d Slope restricted to ≥1.

e Betas restricted to ≥0.

AIC = Akaike’s Information Criterion; BMD = maximum likelihood estimate of the dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD

Source: CMA 1989

The dose-response curve is shown in Figure A-1.

Figure A-1 Fit of Gamma Model to Data on 1,2,4-Trichlorobenzene, Incidence of Centrilobular Hepatocyte Hypertrophy in Male Rats

Source: CMA 1989

## 1,2,4-Trichlorobenzene Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,4-Trichlorobenzene
CAS Number: | 120-82-1
Date: | May 2014
Profile Status: | Final Post-Public Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 38
Species: | Rat

[underlined: Minimal Risk Level]: 0.1 [x] mg/kg/day [ ] ppm

[underlined: Reference]: Moore MR. 1994a. Final report (6 copies), 104-week dietary carcinogenicity study with 1,2,4-trichlorobenzene in rats, with cover letter dated 6/15/94. Chemical Manufacturers Association. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. EPA Document No. OPPTS-44612. OTS0558832.

[underlined: Experimental design]: Groups of Fisher-344 rats (50/sex/group) were fed a diet containing 0, 100, 350, or 1,200 ppm 1,2,4-trichlorobenzene for 104 weeks. The diet provided doses of 0, 5.6, 19.4, or 66.5 mg/kg/day 1,2,4-trichlorobenzene to males and 0, 6.9, 23.5, or 81.4 mg/kg/day 1,2,4-trichlorobenzene to females. Parameters evaluated included mortality (twice daily), clinical signs, body weight and food consumption (weekly for 16 weeks and every 4 weeks thereafter), hematology (week 52 and 78 for cellular morphology and leukocyte differential, from control and high-dose groups), organ weight (at termination, brain, brainstem, liver, kidneys, testes and epididymis), and gross necropsy and histological examination of all major organs and tissues at termination.

[underlined: Effect noted in study and corresponding doses]: Treatment with 1,2,4-trichlorobenzene resulted in a significant reduction in survival rate in males dosed with 66.5 mg/kg/day. Survival rate in the control, 5.6, 19.4, and 66.5 mg/kg/day males at week 104 were 84, 80, 84, and 60% respectively. There were no distinct or pronounced compound-related differences in clinical signs between treated and control groups. Differences in body weight between treated and control rats were <10% throughout the study. Food consumption was decreased 4–7% in treated groups relative to controls during the study. The only statistically significant hematology findings were a decrease in basophiles at week 52 and monocytes at week 105 in males dosed with 66.5 mg/kg/day, which the investigators considered minor. No evidence of leukemia was noted. Gross necropsy at termination showed increased incidence of liver and kidney abnormalities in males dosed with 19.4 and 66.5 mg/kg/day and a slight increase in incidence of uterine masses in treated females relative to controls; these changes were not discussed any further. Significant changes in organ weight were limited to an increase in absolute and relative liver weight in both male and female rats receiving the highest doses of 1,2,4-trichlorobenzene and a decrease in absolute and relative testes weight in males dosed with 5.6 and 19.4 mg/kg/day. Treatment-related histological alterations were restricted to the liver of males and females and to the kidneys of males and consisted of the following: hepatocellular hypertrophy (which probably caused the increase in liver weight), focal cystic degeneration, diffuse fatty change, transitional renal cell hyperplasia, and increased severity of chronic rat nephropathy in males. Incidences of liver lesions are presented in Table A-2 (note that a smaller number of animals from the low-dose groups were examined for histopathology).

Table A-2 Incidence of Liver Lesions in Rats in a 104-Week Dietary Study

Males
Dose (mg/kg/day) | 0 | 5.6 | 19.4 | 66.5
Hepatocellular hypertrophy | 2/50(4%) | 1/26(3.8%) | 5/50(10%) | 30/50(60%)
Focal cystic degeneration | 9/50(18%) | 3/26(11.5%) | 4/50(8%) | 19/50(38%)
Diffuse fatty change | 5/50(10%) | 3/26(11.5%) | 5/50(10%) | 14/50(28%)
Females
Dose (mg/kg/day) | 0 | 6.9 | 23.5 | 81.4
Hepatocellular hypertrophy | 6/50(12%) | 5/25(20%) | 5/50(10%) | 37/50(74%)
Diffuse fatty change | 15/50(30%) | 6/25(24%) | 21/50(42%) | 30/50(60%)

Source: Moore 1994a

The incidences of transitional cell hyperplasia in the kidneys of male rats were as follows: 0/50, 0/19, 2/50, and 34/50 in males dosed with 0, 5.6, 19.4, and 66.5 mg/kg/day 1,2,4-trichlorobenzene, respectively. Since there is strong evidence from the 14-week study (CMA 1989) suggesting that the renal lesions in male rats may represent a male-specific response not relevant for MRL derivation, and that the renal cell hyperplasia reported in the 104-week study is a typical response seen in the male rat nephropathy, renal cell hyperplasia was not considered as a potential end point for MRL derivation.

Table A-2 shows that: (1) diffuse fatty change was significantly increased in males and females only at the highest dose; (2) focal cystic degeneration occurred at lower incidence in the low- and mid-dose males compared to controls, and was significantly increased only at the highest dose; (3) hepatocellular hypertrophy in female rats occurred at increased frequency only at the highest dose; and (4) only hepatocellular hypertrophy in male rats exhibited dose-response characteristics. Based on these facts, only the hepatocellular hypertrophy in male rats was considered for MRL derivation.

[underlined: Dose and end point used for MRL derivation]: BMDL_10_ of 13.33 mg/kg/day for hepatocellular hypertrophy in male rats.

[ ] NOAEL [ ] LOAEL [ X ] BMDL_10_

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Yes, done by the investigators.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Treatment of B6C3F_1_ mice with 1,2,4-trichlorobenzene in the diet for 104 weeks produced hepatocellular carcinoma (Moore 1994b). Two intermediate-duration studies in rats and one in mice also suggested that the liver is a target for 1,2,4-trichlorobenzene (CMA 1989; Côté et al. 1988; Hiles 1989).

[underlined: Agency Contacts (Chemical Managers)]: Obaid Faroon, D.V.M., Ph.D.

#### BENCHMARK MODELING OF HEPATOCELLULAR HYPERTROPHY IN MALE RATS

Models in the EPA Benchmark Software (BMDS version 2.1) were fit to the data set for hepatocellular hypertrophy in the liver of male rats. A BMR of 10% was selected in the absence of data that would support a lower BMR. In accordance with EPA (2000a) guidance, BMDs and BMDLs associated with an extra risk of 10% are calculated for all models. Adequate model fit is judged by three criteria: goodness-of-fit (p>0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined BMR. Among all of the models providing adequate fit to the data, the BMDL from the model with the lowest AIC is chosen. Details of the modeling are presented below in Table A-3 and Figure A-2.

Table A-3 Model Predictions for the Incidence of Hepatocellular Hypertrophy in Male Rats

Model | χ^2^ Goodness of fit p-value^a^ | AIC | BMD_10_ (mg/kg/day) | BMDL^10^ (mg/kg/day)
Gamma^b^ | 0.92 | 131.09 | 23.40 | 13.76
Logistic | 0.95 | 129.18 | 25.44 | 20.54
Log-Logistic^c^ | 0.91 | 131.10 | 23.34 | 14.03
Log-Probit^c^ | 0.96 | 131.08 | 22.72 | 14.39
Multistage (1-degree)^d^ | 0.06 | 135.48 | 10.13 | 7.62
Multistage (2-degree) ^d^ ^,^ ^e^ | 0.98 | 129.12 | 23.25 | 13.33
Multistage (3-degree)^d^ | 0.87 | 131.11 | 23.94 | 13.02
Probit | 0.92 | 129.24 | 22.92 | 18.65
Weibull^b^ | 0.88 | 131.11 | 23.95 | 13.62
Quantal-Linear | 0.06 | 135.48 | 10.13 | 7.62

a Values <0.10 fail to meet conventional goodness-of-fit criteria.

b Power restricted to ≥1.

c Slope restricted to ≥1.

d Betas restricted to ≥0.

e Best-fitting model. Among models with adequate fit, the model with the lowest AIC was selected (Multistage 2-degree model).

AIC = Akaike’s Information Criterion; BMD = maximum likelihood estimate of the dose/concentration associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD

Source: Moore 1994a

In accordance with the selection criteria mentioned above, the Multistage (2-degree) model was selected for MRL derivation. The dose-response curve is shown in Figure A-2.

Figure A-2 Fit of Multistage (2-degree) Model to Data on 1,2,4-Trichlorobenzene, Incidence of Hepatocellular Hypertrophy in Male Rats

Source: Moore 1994a