# CHAPTER 8 REFERENCES

+ Cited in supplemental document

Abou-Donia MB. 1979. Late acute effect of S,S,S-tributyl phosphorotrithioate (DEF) in hens. Toxicol Lett (Amst) 4(4):231–236.
Abou-Donia MB, Graham DG, Abdo KM, 1979. Delayed neurotoxic, late acute and cholinergic effects of S,S,S-tributyl phosphorotrithioate (DEF): Subchronic (90 days) administration in hens. Toxicology 14(3):229–243.542954
ACGIH. 2018. CAS number index. In: TLVs and BEIs based on the documentation of the threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 233–250.
Albuquerque E, Deshpande S, Kawabuchi M, 1985. Multiple actions of anticholinesterase agents on chemosensitive synapses: Molecular basis for prophylaxis and treatment of organophosphate poisoning. Toxicol Sci 5(6part2):182–203.
Aldridge JE, Levin ED, Seidler FJ, 2005. Developmental exposure of rats to chlorpyrifos leads to behavioral alterations in adulthood, involving serotonergic mechanisms and resembling animal models of depression. Environ Health Perspect 113(5):527–531.15866758
Alexander M. 1995. How toxic are toxic chemicals in soil? Environ Sci Technol 29(11):2713–2717.22206515
Ames RG, Gregson J. 1995. Mortality following cotton defoliation: San Joaquin Valley, California, 1970–1990. J Occup Environ Med 37(7):812–819.7552465
Ames RG, Brown SK, Mengle DC, 1989. Cholinesterase activity depression among California agricultural pesticide applicators. Am J Ind Med 15(2):143–150.2729280
Androutsopoulos VP, Hernandez AF, Liesivuori J, 2013. A mechanistic overview of health associated effects of low levels of organochlorine and organophosphorous pesticides. Toxicology 307:89–89. 10.1016/j.tox.2012.09.011.
+Astroff AB, Young AD. 1998. The relationship between maternal and fetal effects following maternal organophosphate exposure during gestation in the rat. Toxicol Ind Health 14(6):869–889.9891917
+Astroff AB, Freshwater KJ, Eigenberg DA. 1998. Comparative organophosphate-induced effects observed in adult and neonatal Sprague-Dawley rats during the conduct of multigeneration toxicity studies. Reprod Toxicol 12(6):619–645.9875697
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
ATSDR. 2002. Toxicological profile for DDT, DDE, and DDD. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/toxprofiles/tp35.pdf. September 11, 2019.
ATSDR. 2017. Tribufos. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/SPL/resources/index.html. September 11, 2019.
Baker LW, Fitzell DL, Seiber JN, 1996. Ambient air concentrations of pesticides in California. Environ Sci Technol 30(4):1365–1368.
Banks CN, Lein PJ. 2012. A review of experimental evidence linking neurotoxic organophosphorus compounds and inflammation. Neurotoxicology 33(3):575–584. 10.1016/j.neuro.2012.02.002.22342984
Barbash J, Resek EA. 1996. Overview of pesticide occurrence and distribution in relation to use. In: Pesticides in ground water: Distribution, trends, and governing factors. Vol. 2. Chelsea, MI: Ann Arbor Press, Inc., 590.
Barber LT, Hayes RM, Dodds DM, 2013. Mid-south cotton defoliation guide. University of Arkansas System, 1–12. https://www.uaex.edu/publications/PDF/MP503.pdf. September 12, 2019.
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Bayer. 2008. US Environmental Protection Agency HPV Challenge Program test plan submission. S,S’,S’-tributyl phosphorotrithioite. CAS No. 150-50-5. Bayer CropScience. Submitted to the U.S. Environmental Protection Agency.
Bigbee JW, Sharma KV. 2004. The adhesive role of acetylcholinesterase (AChE): Detection of AChE binding proteins in developing rat spinal cord. Neurochem Res 29(11):2043–2050.15662838
Bigbee JW, Sharma KV, Chan EL, 2000. Evidence for the direct role of acetylcholinesterase in neurite outgrowth in primary dorsal root ganglion neurons. Brain Res 861(2):354–362.10760497
Bomser JA, Casida JE. 2001. Diethylphosphorylation of rat cardiac M2 muscarinic receptor by chlorpyrifos oxon in vitro. Toxicol Lett 119(1):21–26. 10.1016/s0378-4274(00)00294-0.11275418
Bouchard MF, Chevrier J, Harley KG, 2011. Prenatal exposure to organophosphate pesticides and IQ in 7-year-old children. Environ Health Perspect 119(8):1189–1195. 10.1289/ehp.1003185.21507776
Boyd EM, Carsky E. 1969. Kwashiorkorigenic diet and diazinon toxicity. Acta Pharmacol Toxicol (Copenh) 27:284–294.5394745
CalEPA. 2000. Estimation of exposure of persons in California to pesticide products that contain tribufos. Sacramento, CA: California Environmental Protection Agency. www.cdpr.ca.gov/docs/whs/pdf/hs1552.pdf. April 26, 2016.
+CalEPA. 2004. S.S,S-Tributyl phosphorotrithioate (tribufos) risk characterization document (Revision No. 1). California Environmental Protection Agency. www.cdpr.ca.gov/docs/risk/rcd/def_r1.pdf. April 26, 2016.
CalEPA. 2009. Pesticide air monitoring in Parlier, CA. Sacramento, CA: California Environmental Protection Agency, 22.
CDFA. 2013. Determination of organophosphate pesticides in surface water using gas chromatography with mass selective detection (MSD). Sacramento, CA: California Department of Food and Agriculture, Center for Analytical Chemistry. http://www.cdpr.ca.gov/docs/emon/pubs/anl_methds/emon-sm-46-0-msd.pdf. June 17, 2016.
Chen HH, Sirianni SR, Huang CC. 1982a. Sister-chromatid exchanges and cell-cycle delay in Chinese hamster V79 cells treated with 9 organophosphorus compounds (8 pesticides and 1 defoliant). Mutat Res 103(3–6):307–313.6211614
Chen HH, Sirianni SR, Huang CC. 1982b. Sister chromatid exchanges in Chinese hamster cells treated with seventeen organophosphorus compounds in the presence of a metabolic activation system. Environ Mutagen 4:621–624.7140680
Chou CH, Williams-Johnson M. 1998. Health effects classification and its role in the derivation of minimal risk levels: Neurological effects. Toxicol Ind Health 14(3):455–471.9569449
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Cohen DB. 1986. Ground water contamination by toxic substances. A California assessment. ACS Symp Ser 315:499–499. 10.1021/bk-1986-0315.ch029.
CPCR. 1992. DEF 6 emulsifiable defoliant. In: Crop Protection Chemicals Reference. New York, NY: John Wiley & Sons, Inc., 1158–1159.
Curl CL, Fenske RA, Kissel JC, 2002. Evaluation of take-home organophosphorus pesticide exposure among agricultural workers and their children. Environ Health Perspect 110(12):A787–792.12460819
DOE. 2018. Table 3: Protective Action Criteria (PAC) Rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/docs/Revision_29A_Table3.pdf. July 26, 2018.
Dori A, Cohen J, Silverman WF, 2005. Functional manipulations of acetylcholinesterase splice variants highlight alternative splicing contributions to murine neocortical development. Cerebral Cortex 15(4):419–430.15749986
Eichelberger JW, Lichtenberg JJ. 1971. Persistence of pesticides in river water. Environ Sci Technol 5(6):541–544.
Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15(1):30–38.
Elvers B, Hawkins S, Schulz G. 1992. Plant growth regulators: Merphos, tribufos. In: Ullmann’s encyclopedia of industrial chemistry. Vol. A20. 5th ed. Weinheim, Germany: Wiley-VCH, 424.
EPA. 1981. Acephate, aldicarb, carbophenothion, DEF, EPN, ethoprop, methyl parathion, and phorate: Their acute and chronic toxicity, bioconcentration potential, and persistence as related to marine environments. Gulf Breeze, FL: U.S. Environmental Protection Agency. EPA600481041. https://cfpub.epa.gov/si/si_public_record_Report.cfm?Lab=NHEERL&dirEntryID=30784. November 25, 2019.
EPA. 1987. Data evaluation record. Tribufos. Soil adsorption/desorption with ^14^C-DEF. Mobay Chemical Corporation. Submitted to the U.S. Environmental Protection Agency. Study ID: 41618817.
EPA. 1988. Data evaluation record. S,S,S-Tributyl phosphorotrithioate. Soil surface photolysis of ^14^C DEF in natural sunlight. Mobay Chemical Corporation. Submitted to the U.S. Environmental Protection Agency. Study ID: 41618816.
+EPA. 1990a. Data evaluation report. Oncogenicity study of technical tribufos (DEF) with mice. Memorandum. Tribufos (DEF) review of teratology studies in rat and rabbit and an oncogenicity study in mice. Mobay Chemical Corporation. Submitted to the U.S. Environmental Protection Agency. MRID411710-01.
+EPA. 1990b. Data evaluation report. A teratology study with DEF technical in the rat. Memorandum. Tribufos (DEF) review of teratology studies in rat and rabbit and an oncogenicity study in mice. Miles Laboratories Inc. Submitted to the U.S. Environmental Protection Agency. MRID401906-01.
+EPA. 1990c. Data evaluation report. A teratology study with DEF technical in the rabbit. Memorandum. Tribufos (DEF) review of teratology studies in rat and rabbit and an oncogenicity study in mice. Miles Laboratories Inc. Submitted to the U.S. Environmental Protection Agency. MRID401906-02.
EPA. 1990d. Data evaluation record. Tribufos. The metabolism of tribufos in soil under anaerobic conditions. Mobay Chemical Corporation. Submitted to the U.S. Environmental Protection Agency. Study ID: 42007205.
+EPA. 1991a. Data evaluation report. Acute four-hour inhalation toxicity study with technical grade DEF in rats. Mobay Chemical Corporation. Submitted to the U.S. Environmental Protection Agency. MRID417823-01.
+EPA. 1991b. Memorandum. Tribufos (DEF) chronic dog study and 90-day hen dermal neurotoxicity study. Mobay Chemical Corporation. Submitted to the U.S. Environmental Protection Agency. MRID4420072-03.
EPA. 1991c. Data evaluation record. Tribufos. The metabolism of tribufos in soil under aerobic conditions. Mobay Chemical Corporation. Submitted to the U.S. Environmental Protection Agency. Study ID: 42007204.
+EPA. 1992a. Data review for acute inhalation toxicity testing (81–3). Mobay Chemical Corporation. Submitted to the U.S. Environmental Protection Agency. MRID417823-01.
+EPA. 1992b. Data evaluation report. Study of the subchronic inhalation toxicity to rats in accordance with OECD guideline No. 413. Bayer AG. Submitted to the U.S. Environmental Protection Agency. MRID423998-01.
+EPA. 1992c. A two-generation dietary reproduction study in rats using tribufos (DEF). In: Memorandum. Tribufos (DEF) reproduction studies. Mobay Chemical Corporation. Submitted to the U.S. Environmental Protection Agency. MRID420401-01.
+EPA. 1992d. Technical grade tribufos (DEF): A chronic feeding study in the Fischer 344 rat. In: Memorandum: Tribufos (DEF), rat combined chronic/oncogenicity study. Miles Inc. Submitted to the U.S. Environmental Protection Agency. MRID423351-01.
EPA. 1992e. Pesticides in ground water database. A compilation of monitoring studies: 1971–1991. National summary. U.S. Environmental Protection Agency. EPA7341292001.
+EPA. 1993a. Data review for acute oral toxicity testing (81–1). In: Memorandum: EPA Reg. No.: 3125–96. Mobay Chemical Corporation. Submitted to the U.S. Environmental Protection Agency. MRID419549-03.
+EPA. 1993b. Data review for acute dermal toxicity testing (81–2). In: Memorandum: EPA Reg. No.: 3125–96. Mobay Chemical Corporation. Submitted to the U.S. Environmental Protection Agency. MRID419549-02.
EPA. 1993c. Data review for acute eye irritation testing (81–4). In: Memorandum: EPA Reg. No.: 3125–96. Miles Inc. Submitted to the U.S. Environmental Protection Agency. MRID419549-01.
+EPA. 1993d. 21-Day dermal toxicity study with technical grade tribufos (DEF) in rabbits. In: Tribufos (DEF), 21-day dermal toxicity rabbit. Mobay Chemical Corporation. Submitted to the U.S. Environmental Protection Agency. MRID420072-01.
EPA. 1994. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. Washington, DC: U.S. Environmental Protection Agency. EPA600890066F. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30001K4C.txt. March 20, 2019.
EPA. 1997. Memorandum: Carcinogenicity peer review (2nd) of tribufos (DEF). U.S. Environmental Protection Agency.
EPA. 2000a. Human health risk assessment. Tribufos. U.S. Environmental Protection Agency. https://www3.epa.gov/pesticides/chem_search/hhbp/R008352.pdf. April 26, 2016.
EPA. 2000b. A dermal/intravenous crossover study to determine the dermal absorption of [^14^C]-DEF 6 (S,S,S-tributylphosphorotrothioate in male rhesus monkeys. Tribufos (DEF). Review of a dermal absorption study in the Rhesus monkey. Sierra Biomedical. Submitted to the U.S. Environmental Protection Agency. MRID450199-01.
+EPA. 2005a. Data evaluation record. Tribufos. Study type: Developmental neurotoxicity study-rat; OPPTS 870.6300. Bayer Corporation. Submitted to the U.S. Environmental Protection Agency. MRID45499501/0050231.
EPA. 2005b. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001. https://ofmpub.epa.gov/apex/guideme_ext/guideme_ext/guideme/file/ry_2004_rfi.pdf. September 17, 2019.
EPA. 2006a. Organophosphorus cumulative risk assessment. 2006 Update. U.S. Environmental Protection Agency. https://www.regulations.gov/document?D=EPA-HQ-OPP-2006-0618-0002. September 13, 2016.
EPA. 2006b. Reregistration eligibility decision for tribufos. U.S. Environmental Protection Agency. https://www3.epa.gov/pesticides/chem_search/reg_actions/reregistration/red_PC-074801_31-Jul-06.pdf. February 25, 2015.
EPA. 2008. Risks of tribufos use to federally threatened California red-legged frog (Rana aurora draytonii). Pesticide effects determination. Washington, DC: U.S. Environmental Protection Agency. https://www3.epa.gov/pesticides/endanger/litstatus/effects/redlegfrog/tribufos/determination.pdf. September 17, 2019.
EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. September 7, 2017.
+EPA. 2012a. Data evaluation record. Tribufos: Non-guideline acute and repeat dose-range finding studies in PND 11 rat pups. AMVAC Chemical Corporation. Submitted to the U.S. Environmental Protection Agency. MRID48709901.
+EPA. 2012b. Data evaluation record. Tribufos: Acute oral dosing in neonatal rats-time to peak effect. AMVAC Chemical Corporation. Submitted to the U.S. Environmental Protection Agency. MRID48709902.
+EPA. 2012c. Data evaluation record. Tribufos: Acute oral dosing to young adult rats-time to peak effect non-guideline. AMVAC Chemical Corporation. Submitted to the U.S. Environmental Protection Agency. MRID48709903.
+EPA. 2012d. Data evaluation record. Tribufos: Acute oral dosing adult and pup comparative ChE non-guideline. AMVAC Chemical Corporation. Submitted to the U.S. Environmental Protection Agency. MRID48709904.
+EPA. 2012e. Data evaluation record. Tribufos: Repeat dose comparative sensitivity study in young adult female and 11 day old neonatal CD rats by oral gavage administration non guideline. AMVAC Chemical Corporation. Submitted to the U.S. Environmental Protection Agency. MRID48709905.
+EPA. 2012f. Data evaluation record. Tribufos: Gestational ChE inhibition [gavage]-rat; non-guideline. AMVAC Chemical Corporation. Submitted to the U.S. Environmental Protection Agency. MRID48709906.
EPA. 2012g. Method 525.3. Determination of semivolatile organic chemicals in drinking water by solid phase extraction and capillary column gas chromatography/mass spectrometry (GC/MS). U.S. Environmental Protection Agency. EPA600R12010. https://cfpub.epa.gov/si/si_public_record_report.cfm?Lab=NERL&dirEntryId=241188&simpleSearch=1&searchAll=525.3. September 11, 2019.
EPA. 2012h. Estimations Programs Interface Suite^TM^ for Microsoft® Windows, v 4.11. Washington, DC: U.S. Environmental Protection Agency. https://www.epa.gov/tsca-screening-tools/epi-suitetm-estimation-program-interface. September 19, 2019.
+EPA. 2013. Data evaluation record. Tribufos technical: 4-week dietary immunotoxicity study in female Han Wistar rat. AMVAC Chemical Corporation. Submitted to the U.S. Environmental Protection Agency. MRID48709907.
EPA. 2014. Tribufos: Validation of analytical methodology for the determination of residues in soil and sediment and MRID: 48822503. Tribufos: Independent laboratory validation of methodology for the determination of residues of tribufos in soil (sandy loam and clay loam) and sediment (sandy silt loam). U.S. Environmental Protection Agency. MRID48822501.
EPA. 2015a. Part 180 - Tolerances and exemptions for pesticide chemical residues in food. Subpart C - Specific tolerances. Tribuphos; tolerances for residues. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.272. https://www.gpo.gov/fdsys/pkg/CFR-2015-title40-vol24/pdf/CFR-2015-title40-vol24-sec180-272.pdf. March 28, 2016.
EPA. 2016. Phosphorotrithioic acid, S,S,S-tributyl ester. Chemical Data Access Tool (CDAT). U.S. Environmental Protection Agency. http://java.epa.gov/oppt_chemical_search/. January 27, 2016.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories tables. Washington, DC: U.S. Environmental Protection Agency. EPA822F18001. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf. November 22, 2019.
EPA. 2018b. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. June 5, 2019.
EPA. 2019a. ChemView. Chemical data reporting year: 2016. Phosphorotrithioic acid, S,S,S-tributyl ester. U.S. Environmental Protection Agency https://chemview.epa.gov/chemview?tf=0&ch=78-48-8&su=2-5-6-7-37574985&as=3-10-9-8&ac=1-15-16-6378999&ma=4-11-1981377&tds=0&tdl=10&tas1=1&tas2=asc&tas3=undefined&tss=&modal=template&modalId=96719&modalSrc=4&modalDetailId=35877454&modalCdr=96719. September 11, 2019.
EPA. 2019b. The fourth Unregulated Contaminant Monitoring Rule (UCMR 4): Data summary, July 2019. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-10/documents/ucmr4-data-summary.pdf. September 11, 2019.
EPA. 2019c. Part 180 - Tolerances and exemptions for pesticide chemical residues in food. Subpart C - Specific tolerances. Tribuphos; tolerances for residues. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.272. https://gov.ecfr.io/cgi-bin/retrieveECFR?gp=1&SID=9469e7103e6ef004543cafec0bdcef6b&ty=HTML&h=L&mc=true&r=SECTION&n=se40.26.180_1272. September 4, 2019.
Farahat FM, Ellison CA, Bonner MR, 2011. Biomarkers of chlorpyrifos exposure and effect in Egyptian cotton field workers. Environ Health Perspect 119(6):801–806. 10.1289/ehp.1002873.21224175
FDA. 2001. Pesticide residue monitoring program 2001. U.S. Food and Drug Administration. http://www.fda.gov/Food/FoodborneIllnessContaminants/Pesticides/ucm125173.htm. January 20, 2017.
FDA. 2006. Total diet study. Market baskets 1991–3 through 2003–4. College Park, MD: U.S. Food and Drug Administration. https://www.fda.gov/media/77958/download. November 25, 2019.
FDA. 2013. Pesticide monitoring program fiscal year 2013 pesticide report. U.S. Food and Drug Administration. http://www.fda.gov/Food/FoodborneIllnessContaminants/Pesticides/ucm506932.htm. January 2017.
FDA. 2019. Substances added to food. Washington, DC: U.S. Food and Drug Administration. https://www.accessdata.fda.gov/scripts/fdcc/?set=FoodSubstances. September 2, 2019.
Fendinger NJ, Glotfelty DE. 1990. Henry’s law constants for selected pesticides, PAHs and PCBs. Environ Toxicol Chem 9(6):731–735. 10.1002/etc.5620090606.
Francis BM, Metcalf RL, Hansen LG. 1985. Toxicity of organophosphorus esters to laying hens after oral and dermal administration. J Environ Sci Health Part B Pestic Food Contam Agric Wastes 20(1):73–96.
Fujioka K, Casida JE. 2007. Glutathione S-transferase conjugation of organophosphorus pesticides yields S-phospho-, S-aryl-, and S-alkylglutathione derivatives. Chem Res Toxicol 20(8):1211–1217. 10.1021/tx700133c.17645302
+Gaines TB. 1969. Acute toxicity of pesticides. Toxicol Appl Pharmacol 14(3):515–534.5787520
Garry VF. 2004. Pesticides and children. Toxicol Appl Pharmacol 198(2):152–163.15236951
Gartrell MJ, Craun JC, Podrebarac DS, 1986. Pesticides, selected elements, and other chemicals in adult total diet samples, October 1980-March 1982. J Assoc Off Anal Chem 69(1):146–161.3949687
Glotfelty DE, Seiber JN, Liljedahl LA. 1987. Pesticides in fog. Nature 325(6105):602–605.3808063
Gunderson FL. 1988. FDA Total Diet Study, April 1982-April 1984, dietary intakes of pesticides, selected elements, and other chemicals. J Assoc Off Anal Chem 71(6):1200–1209.3240978
Gunderson EL. 1995a. Dietary intakes of pesticides, selected elements, and other chemicals: FDA Total Diet Study, June 1984-April 1986. J AOAC Int 78(4):910–920.7580329
Gunderson EL. 1995b. FDA Total Diet Study, July 1986-April 1991, dietary intakes of pesticides, selected elements, and other chemicals. J AOAC Int 78(6):1353–1362.8664570
Gunier RB, Bradman A, Harley KG, 2016. Prenatal residential proximity to agricultural pesticide use and IQ in 7-Year-old children. Environ Health Perspect 125(5):057002. 10.1289/ehp504.
Hermann BW, Seiber JN. 1981. Sampling and determination of S,S,S-tributyl phosphorotrithioate, dibutyl disulfide and butyl mercaptan in field air. Anal Chem 53(7):1077–1082.
HSDB. 2010. Tribufos (CASRN 78-48-8). Hazardous Substances Databank. National Library of Medicine. http://toxnet.nlm.nih.gov/cgi-bin/sis/search2/r?dbs+hsdb:@term+@DOCNO+668. March 20, 2019.
Hundley HK, Cairns T, Luke MA, 1988. Pesticide residue findings by the Luke Method in domestic and imported foods and animal feeds for fiscal years 1982–1986. J Assoc Off Anal Chem 71(5):875–892.3235407
Hur JH, Wu SY, Casida JE. 1992. Oxidative chemistry and toxicology of S,S,S-tributyl phosphorotrithioate (DEF defoliant). J Agric Food Chem 40(9):1703–1709.
Husain K. 2014. Delayed neurotoxicity of organophosphorus compounds. J Environ Immunol Toxicol 1:14–21.
IARC. 2019. Agents classified by the IARC Monographs, Volumes 1–124. Lyon, France: International Agency for Research on Cancer. https://monographs.iarc.fr/list-of-classifications. September 2, 2019.
Jett D, Abdallah E, El-Fakahany E, 1991. High-affinity activation by paraoxon of a muscarinic receptor subtype in rat brain striatum. Pestic Biochem Physiol 39(142):149–157.
Johnson FO, Chambers JE, Nail CA, 2009. Developmental chlorpyrifos and methyl parathion exposure alters radial-arm maze performance in juvenile and adult rats. Toxicol Sci 109(1):132–142. 10.1093/toxsci/kfp053.19293373
Kilgore W, Fischer C, Rivers J, 1984. Human exposure to DEF/merphos. Residue Rev 91:71–101.6385171
Kolpin DW, Blazer VS, Gray JL, 2013. Chemical contaminants in water and sediment near fish nesting sites in the Potomac River basin: Determining potential exposures to smallmouth bass (Micropterus dolomieu). Sci Total Environ 443:700–716.23228716
Krishnan K, Anderson ME, Clewell HJ, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kuklenyik P. 2009. Dissertation. Detection and quantification of organophosphate pesticides in human serum. Georgia State University. http://scholarworks.gsu.edu/cgi/viewcontent.cgi?article=1045&context=chemistry_diss. April 26, 2016.
Lee S, McLaughlin R, Harnly M, 2002. Community exposures to airborne agricultural pesticides in California: Ranking of inhalation risks. Environ Health Perspect 110(12):1175–1184.12460795
Levi PE, Hodgson E. 1985. Oxidation of pesticides by purified cytochrome p-450 isozymes from mouse liver. Toxicol Lett (Amst) 24(2–3):221–228.
Levin ED, Addy N, Nakajima A, 2001. Persistent behavioral consequences of neonatal chlorpyrifos exposure in rats. Brain Res Dev Brain Res 130(1):83–89.11557096
Little RA, Ray DE. 1979. Tributyl S,S,S-phosphotrithiolate (DEF), a potential tool in thermoregulation research. Br J Pharmacol 66(3):438P.
Loewenherz C, Fenske RA, Simcox NJ, 1997. Biological monitoring of organophosphorus pesticide exposure among children of agricultural workers in Central Washington state. Environ Health Perspect 105(12):1344–1353. 10.2307/3433754.9405329
Lotti M, Becker CE, Aminoff MJ, 1983. Occupational exposure to the cotton defoliants DEF and merphos. A rational approach to monitoring organophosphorous-induced delayed neurotoxicity. J Occup Med 25(7):517–522.6886854
Lu C, Fenske RA, Simcox NJ, 2000. Pesticide exposure of children in an agricultural community: Evidence of household proximity to farmland and take home exposure pathways. Environ Res 84(3):290–302. 10.1006/enrs.2000.4076.11097803
Majewski MS, Foreman WT, Goolsby DA, 1998. Airborne pesticide residues along the Mississippi River. Environ Sci Technol 32(23):3689–3698.
Mamczarz J, Pescrille JD, Gavrushenko L, 2016. Spatial learning impairment in prepubertal guinea pigs prenatally exposed to the organophosphorus pesticide chlorpyrifos: Toxicological implications. Neurotoxicology 56:17–17. 10.1016/j.neuro.2016.06.008.27296654
Marks AR, Harley K, Bradman A, 2010. Organophosphate pesticide exposure and attention in young Mexican-American children: The CHAMACOS study. Environ Health Perspect 118(12):1768–1774. 10.1289/ehp.1002056.21126939
Meylan WM, Howard PH. 1993. Computer estimation of the atmospheric gas-phase reaction rate of organic compounds with hydroxyl radicals and ozone. Chemosphere 26(12):2293–2299.
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 15–35.
NIOSH. 2018. NIOSH pocket guide to chemical hazards: CAS No. 78-48-8. Atlanta, GA: U.S. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgdcas.html. September 2, 2019.
NPIRS. 2019. Federal pesticide products. National Pesticide Information Retrieval System. http://npirspublic.ceris.purdue.edu/ppis/chemical2.aspx. September 11, 2019.
NRA. 1998. NRA special review of tribufos (DEF). Kingston, Australia: National Registration Authority. NRA Special Review Series 98.1. https://apvma.gov.au/sites/default/files/publication/14831-tribufos-special-review-report.pdf. September 19, 2019.
NTP. 2016. Report on carcinogens, Fourteenth edition. CASRN Index in MS Excel. Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#P. March 1, 2017.
OSHA. 2018a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1910/1910.1000TABLEZ1. November 28, 2018.
OSHA. 2018b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal. Regulations 29 CFR 1915.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1915/1915.1000. November 1, 2018.
OSHA. 2018c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55 Appendix A. https://www.osha.gov/laws-regs/regulations/standardnumber/1926/1926.55AppA. November 1, 2018.
Parkinson A, Ogilvie BW. 2008. Biotransformation of xenobiotics. In: Klaassen CD, ed. Casarett and Doull’s toxicology: The basic science of poisons. 7th ed. New York, NY: McGraw-Hill, 161–304.
Pereira EF, Aracava Y, DeTolla LJ, 2014. Animal models that best reproduce the clinical manifestations of human intoxication with organophosphorus compounds. J Pharmacol Exp Ther 350(2):313–321. 10.1124/jpet.114.214932.24907067
Potter TL, Mohammed MA, Ali H. 2007. Solid-phase extraction combined with high-performance liquid chromatography-atmospheric pressure chemical ionization-mass spectrometry analysis of pesticides in water: Method performance and application in a reconnaissance survey of residues in drinking water in Greater Cairo, Egypt. J Agric Food Chem 55(2):204–210.17227043
Potter TL, Reddy KN, Millhollen EP, 2002. Dissipation of the defoliant tribufos in cotton-producing soils. J Agric Food Chem 50(13):3795–3802.12059162
Potter TL, Truman CC, Bosch DD, 2003. Cotton defoliant runoff as a function of active ingredient and tillage. J Environ Qual 32(6):2180–2188.14674540
Rauh VA, Garcia WE, Whyatt RM, 2015. Prenatal exposure to the organophosphate pesticide chlorpyrifos and childhood tremor. Neurotoxicology 51:80–80. 10.1016/j.neuro.2015.09.004.26385760
Rauh VA, Perera FP, Horton MK, 2012. Brain anomalies in children exposed prenatally to a common organophosphate pesticide. Proc Natl Acad Sci USA 109(20):7871–7876. 10.1073/pnas.1203396109.22547821
Ray DE. 1980. Selective inhibition of thermogenesis by tributyl S,S,S,-phosphorotrithioate (DEF). Br J Pharmacol 69(2):257–264.7437638
Ray DE. 1998. Chronic effects of low level exposure to anticholinesterases - A mechanistic review. Toxicol Lett 102–103:527–533.10022307
Ray DE, Cunningham VJ. 1985. Hypothermia produced by tributyl S,S,S-phosphorotrithioate (DEF). Arch Toxicol 56(4):279–282.3994512
RePORTER. 2019. Tribufos. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. September 9, 2019.
Rosas LG, Eskenazi B. 2008. Pesticides and child neurodevelopment. Curr Opin Pediatr 20(2):191–197. 10.1097/MOP.0b013e3282f60a7d.18332717
Ross SM, McManus IC, Harrison V, 2013. Neurobehavioral problems following low-level exposure to organophosphate pesticides: A systematic and meta-analytic review. Crit Rev Toxicol 43(1):21–44. 10.3109/10408444.2012.738645.23163581
Sahali Y, Jett CM, Murphy JJ. 1994. Metabolic fate of S,S,S-tributyl phosphorotrithioate (DEF) in the lactating goat. Xenobiotica 24(4):301–313.8059534
Scarborough ME, Ames RG, Lipsett MJ, 1989. Acute health effects of community exposure to cotton defoliants. Arch Environ Health 44(6):355–360.2610523
Silman I, Sussman JL. 2005. Acetylcholinesterase: ‘Classical’ and ‘non-classical’ functions and pharmacology. Curr Opin Pharmacol 5(3):293–302. 10.1016/j.coph.2005.01.014.15907917
Singleton ST, Lein PJ, Dadson OA, 2015. Longitudinal assessment of occupational exposures to the organophosphorous insecticides chlorpyrifos and profenofos in Egyptian cotton field workers. Int J Hyg Environ Health 218(2):203–211. 10.1016/j.ijheh.2014.10.005.25466362
Stein LJ, Gunier RB, Harley K, 2016. Early childhood adversity potentiates the adverse association between prenatal organophosphate pesticide exposure and child IQ: The CHAMACOS cohort. Neurotoxicology 56:180–180. 10.1016/j.neuro.2016.07.010.27474229
Sternfeld M, Ming G, Song H, 1998. Acetylcholinesterase enhances neurite growth and synapse development through alternative contributions of its hydrolytic capacity, core protein, and variable C termini. J Neurosci 18(4):1240–1249. 10.1523/JNEUROSCI.18-04-01240.1998.9454834
Terry AV. 2012. Functional consequences of repeated organophosphate exposure: Potential non-cholinergic mechanisms. Pharmacol Ther 134(3):355–365. 10.1016/j.pharmthera.2012.03.001.22465060
Tomlin CDS. 2003. Tribufos (823). Plant growth regulator. In: The e-pesticide manual. Version 3.0. 13th ed. British Crop Protection Council, 1–2.
TRI17. 2019. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Toxics Release Inventory. U.S. Environmental Protection Agency. http://www.epa.gov/triexplorer/. September 9, 2019.
Ueyama J, Wang D, Kondo T, 2007. Toxicity of diazinon and its metabolites increases in diabetic rats. Toxicol Lett 170:229–237.17442507
USDA. 2010. Field crops. Usual planting and harvesting dates. October 2010. U.S. Department of Agriculture. http://usda.mannlib.cornell.edu/usda/current/planting/planting-10-29-2010.pdf. January 16, 2017.
USDA. 2016a. Statistics by subject. Cotton. All cotton acres United States. U.S. Department of Agriculture. https://www.nass.usda.gov/Charts_and_Maps/graphics/cotnac.pdf. July 12, 2016.
USDA. 2016b. Pesticide data program. Annual summary, calendar year 2014. Washington, DC: U.S. Department of Agriculture. https://www.ams.usda.gov/sites/default/files/media/2014%20PDP%20Annual%20Summary.pdf. April 26, 2016.
USGS. 2002. Sediment deposition and selected water-quality characteristics in Cedar Lake and Lake Olathe, Northeast Kansas, 2000. U.S. Geological Survey, U.S. Department of the Interior. 10.3133/wri024073.
USGS. 2008. Pesticide occurrence and distribution in the lower Clackamas River Basin, Oregon, 2000-2005. Scientific investigation report 2008–5027. Reston, VA: U.S. Geological Survey, U.S. Department of the Interior. https://pubs.usgs.gov/sir/2008/5027/. September 19, 2019.
USGS. 2019. Pesticide national synthesis project. Pesticide use maps - tribufos. U.S. Geological Survey, U.S. Department of the Interior. https://water.usgs.gov/nawqa/pnsp/usage/maps/show_map.php?year=2013&map=TRIBUFOS&hilo=L&disp=Tribufos. September 11, 2019.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
Winchell MF, Snyder NJ. 2014. Comparison of simulated pesticide concentrations in surface drinking water with monitoring data: Explanations for observed differences and proposals for a new regulatory modeling approach. J Agric Food Chem 62(2):348–359. 10.1021/jf4036996.24328205
Wing KD, Glickman AH, Casida JE. 1983. Oxidative bio activation of s-alkyl phosphorothiolate pesticides: Stereospecificity of profenofos insecticide activation. Science 219(4580):63–65.6849116
Wing KD, Glickman AH, Casida JE. 1984. Phosphorothiolate pesticides and related compounds: Oxidative bioactivation and aging of the inhibited acetylcholinesterase. Pestic Biochem Physiol 21(1):22–30.
Wofford P, Segawa R, Schreider J, 2014. Community air monitoring for pesticides. Part 3: Using health-based screening levels to evaluate results collected for a year. Environ Monit Assess 186(3):1355–1370. 10.1007/s10661-013-3394-x.24370859
Woodrow JF, Crosby DG, Seiber JN. 1983. Vapor-phase photochemistry of pesticides. Residue Rev 85:111–125.