# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Rae T. Benedict, Ph.D. (Lead)
- G. Daniel Todd, Ph.D.
- Malcolm Williams, D.V.M., Ph.D.
- ATSDR, Division of Toxicology and Human Health Sciences, Atlanta, GA

- David W. Wohlers, Ph.D.
- Mario Citra, Ph.D.
- SRC, Inc., North Syracuse, NY

## REVIEWERS

- Interagency Minimal Risk Level Workgroup:
  Includes ATSDR; National Center for Environmental Health (NCEH); National Institute of Occupational Health and Safety (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).
- Additional reviews for science and/or policy:
  ATSDR, Division of Community Health Investigations; ATSDR, Office of Science; NCEH, Division of Laboratory Science; NCEH, Division of Environmental Health Science and Practice; EPA/Office of Pesticide Programs.

## PEER REVIEWERS

1. Edna F. Pereira, Ph.D., Associate Professor, University of Maryland School of Medicine, Baltimore, Maryland;
2. Michael Eddleston, M.D., Ph.D., Department of Pharmacology, Toxicology, and Therapeutics, University/BHF Centre for Cardiovascular Science, University of Edinburgh, Edinburgh, United Kingdom; and
3. Richard A Fenske, Ph.D., M.P.H., Associate Chair, Environmental and Occupational Health Sciences, Professor, Environmental and Occupational Health Sciences, University of Washington, Seattle, Washington.

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile’s final content. The responsibility for the content of this profile lies with ATSDR.