# VERSION HISTORY

Date | Description
March 2020 | Final toxicological profile released
September 2017 | Draft for public comment toxicological profile released