# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding tribufos in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for tribufos.

Table 7-1 Regulations and Guidelines Applicable to Tribufos

Agency | Description | Information | Reference
Air
EPA | RfC | No data | EPA 2000a, 2006
WHO | Air quality guidelines | No data | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | No data | EPA 2018a
EPA | National primary drinking water regulations | No data | EPA 2009
EPA | Acute RfD | 0.01 mg/kg/day^a^ | EPA 2000a
EPA | Chronic RfD | 0.001 mg/kg/day^b^
EPA | Tolerances for pesticide chemical residues in or on food commodities | | EPA 2019c
EPA | Milk | 0.01 ppm
EPA | Meat/meat byproducts (cattle, goat, hog, horse, sheep) | 0.02 ppm
EPA | Fat (cattle, goat, hog, horse, sheep) | 0.15 ppm
EPA | Undelinted cottonseed | 4 ppm
EPA | Cotton gin byproducts | 40 ppm
WHO | Drinking water quality guidelines | No data | WHO 2017
FDA | Substances Added to Food | No data^c^ | FDA 2019
Cancer
HHS | Carcinogenicity classification | No data | NTP 2016
EPA | Carcinogenicity classification | Unlikely human carcinogen at low doses; likely human carcinogen at high doses | EPA 1997
IARC | Carcinogenicity classification | No data | IARC 2019
Occupational
ACGIH | TLV (TWA) | No data | ACGIH 2018
OSHA | PEL (8-hour TWA) for general industry, shipyards, and construction | No data | OSHA 2018a
OSHA | PEL (8-hour TWA) for shipyards and construction | No data | OSHA 2018b
OSHA | PEL (8-hour TWA) for construction | No data | OSHA 2018c
NIOSH | REL (up to 10-hour TWA) | No data | NIOSH 2018
Emergency Criteria
EPA | AEGLs-air | No data | EPA 2018b
DOE | PACs-air | No data | DOE 2018

a The acute RfD of 0.01 mg/kg/day was derived from a NOAEL of 1 mg/kg/day based on decreases in plasma, and a LOAEL of 7 mg/kg/day for RBC ChE activity in a prenatal developmental toxicity study in rats.

b The chronic RfD of 0.001 mg/kg/day was derived from a NOAEL of 0.1 mg/kg/day based on plasma ChE inhibition in a chronic toxicity study in dogs.

c The Substances Added to Food inventory replaces the EAFUS list.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; ChE = cholinesterase; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FAO = Food and Agricultural Organization of the United Nations; FDA = Food and Drug Administration; FQPA = Food Quality Protection Act; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; LOAEL = Lowest observed adverse effect level; NIOSH = National Institute for Occupational Safety and Health; NOAEL = No observed adverse effect level; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PAD = population adjusted dose; PEL = permissible exposure limit; RBC = red blood cell; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit value; TWA = time-weighted average; WHO = World Health Organization