# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Table 4-1 lists common synonyms, trade names, and other pertinent identification information for tribufos.

Table 4-1 Chemical Identity of Tribufos

Characteristic | Information | Reference
Chemical name | S,S,S-Tributyl phosphorotrithioate | EPA 2006b
Synonym(s) and registered trade name(s) | Butifos; butiphos; butyl phophorotrithioate; merphos oxide; tribufos; tribuphos; DEF; DEF 6; Folex | CalEPA 2004; EPA 2006b
Chemical formula | C_12_H_27_OPS_3_ | EPA 2006b
Chemical formula | C_12_H_27_OPS_3_ | EPA 2006b
Chemical structure | [image] | EPA 2006b
CAS Registry Number | 78-48-8 | EPA 2006b

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Tribufos is a colorless to pale yellow liquid with a strong mercaptan-like odor that arises from butyl disulfide and butyl mercaptan that are formulation impurities and degradation products of tribufos (NRA 1998). Table 4-2 lists important physical and chemical properties of tribufos.

Table 4-2 Physical and Chemical Properties of Tribufos

Property | Information | Reference
Molecular weight | 314.54 | Tomlin 2003
Color | Colorless to pale yellow | Tomlin 2003
Physical state | Liquid | Tomlin 2003
Melting point | −<25°C | Tomlin 2003
Boiling point | 210°C at 750 mm Hg | Tomlin 2003
Density at 20°C | 1.057 at 20°C | Tomlin 2003
Odor | Mercaptan-like odor | Tomlin 2003
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 20°C | 2.3 mg/L at 20°C | Tomlin 2003
Organic solvents | Soluble in aliphatic, aromatic, and chlorinated hydrocarbons and alcohols; completely miscible in dichloromethane, n-hexane, 2-propanol, and toluene | Tomlin 2003
Partition coefficients:
Log K_ow_ | 5.7 | Tomlin 2003
Log K_oc_ | 3.7–4.10 | EPA 1987
Vapor pressure at 25°C | 5.3×10^−6^ mm Hg | Tomlin 2003
Henry’s law constant at 25°C | 2.94×10^−7^ atm-m^3^/mole | Fendinger and Glotfelty 1990
Autoignition temperature | No data
Flashpoint | No data
Flammability limits | No data
Conversion factors | 1 μg/m^3^ = 0.078 ppbv; 1 ppbv = 12.82 μg/m^3^ | Calculated using the ideal gas law and assuming temperature of 25°C and 1 atm
Explosive limits | No data