# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR TRIBUFOS

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to tribufos.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen were conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for tribufos. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of tribufos have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of tribufos are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

Health Effects; Species; Human; Laboratory mammals; Route of exposure; Inhalation; Oral; Dermal (or ocular); Parenteral (these studies will be considered supporting data); Health outcome; Death; Systemic effects; Body weight effects; Respiratory effects; Cardiovascular effects; Gastrointestinal effects; Hematological effects; Musculoskeletal effects; Hepatic effects; Renal effects; Dermal effects; Ocular effects; Endocrine effects; Immunological effects; Neurological effects; Reproductive effects; Developmental effects; Other noncancer effects; Cancer
Toxicokinetics; Absorption; Distribution; Metabolism; Excretion; PBPK models
Biomarkers; Biomarkers of exposure; Biomarkers of effect
Interactions with other chemicals
Potential for human exposure; Releases to the environment; Air; Water; Soil; Environmental fate; Transport and partitioning; Transformation and degradation; Environmental monitoring; Air; Water; Sediment and soil; Other media; Biomonitoring; General populations; Occupation populations

### B.1.1 Literature Search

The current literature search was intended to update the draft toxicological profile for tribufos released for public comment in 2018. The following main databases were searched in March 2019:

- PubMed
- National Library of Medicine’s TOXLINE
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for tribufos. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to tribufos were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
03/2019 | ((78-48-8[rn] OR “butyl phosphorotrithioate”[nm] OR “B 1,776”[tw] OR “B 1776”[tw] OR “Butifos”[tw] OR “Butiphos”[tw] OR “Butyl phosphorotrithioate”[tw] OR “butyphos”[tw] OR “DEF 6”[tw] OR “DEF Defoliant”[tw] OR “De-Green”[tw] OR “E-Z-Off D”[tw] OR “Fosfall”[tw]OR “Fos-Fall A”[tw] OR “Fossfall”[tw] OR “Ortho phosphate defoliant”[tw] OR “Phosphorotrithioic acid, S, S, S-tributyl ester”[tw] OR “S, S, S-Tributyl phosphorotrithioate”[tw] OR “S, S, S-Tributyl trithiophosphate”[tw] OR “S, S, S-Tributylphosphorotrithioate”[tw] OR “S, S, S-Tributyltrithiophosphate”[tw] OR “TBPT”[tw] OR “TBTP”[tw] OR “Tribufos”[tw] OR “Tribuphos”[tw] OR “Tributyl phosphorotrithioate”[tw] OR “tributyl S, S, S-phosphorotrithioate”[tw] OR “Tributyl trithiophosphate”[tw] OR “Tributylphosphorotrithioate”[tw] OR “Tributyltrithiophosphate”[tw] OR (“DEF”[tw] AND (defoliant OR defoliants OR “Defoliants, Chemical”[mh] OR “Defoliants, Chemical”[pa])) OR (“Phosphorotrithioic”[tw] AND (“tributyl”[tw] OR “butyl”[tw]))) AND (2014/12/01 : 3000[dp] OR 2015/12/01 : 3000[mhda] OR 2015/12/01 : 3000[crdat] OR 2015/12/01 : 3000[edat])) OR (“DEF, total”[tw] OR “Merphos oxide”[tw] OR “S,S,S-Tributyl phosphorotrithioic acid”[tw] OR “Tributyl phosphorotrithioic acid”[tw])
Toxline
03/2019 | Year of Publication 2014 through 2019 (78-48-8[rn] OR “B 1,776” OR “B 1776” OR “Butifos” OR “Butiphos” OR “Butyl phosphorotrithioate” OR “butyphos” OR “DEF 6” OR “DEF Defoliant” OR “De-Green” OR “E-Z-Off D” OR “Fosfall” OR “Fos-Fall A” OR “Fossfall” OR “Ortho phosphate defoliant” OR “Phosphorotrithioic acid, S,S,S-tributyl ester” OR “S,S,S-Tributyl phosphorotrithioate” OR “S,S,S-Tributyl trithiophosphate” OR “S,S,S-Tributylphosphorotrithioate” OR “S,S,STributyltrithiophosphate” OR “TBPT” OR “TBTP” OR “Tribufos” OR “Tribuphos” OR “Tributyl phosphorotrithioate” OR “tributyl S,S,S-phosphorotrithioate” OR “Tributyl trithiophosphate” OR “Tributylphosphorotrithioate” OR “Tributyltrithiophosphate”) AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]; (“DEF, total” OR “Merphos oxide” OR “S,S,S-Tributyl phosphorotrithioic acid” OR “Tributyl phosphorotrithioic acid”) AND NOT PubMed [org] AND NOT pubdart [org]
Toxcenter
03/2019 | L1 931 SEA FILE=TOXCENTER 78-48-8; L2 849 SEA FILE=TOXCENTER L1 NOT PATENT/DT; L3 847 SEA FILE=TOXCENTER L2 NOT TSCATS/FS; L4 30 SEA FILE=TOXCENTER L3 AND ED>=20151201; L7 47 SEA FILE=TOXCENTER L3 AND PY>2014; L8 47 SEA FILE=TOXCENTER L4 OR L7 L9 47 DUP REM L8 (0 DUPLICATES REMOVED) ANSWERS ‘1-47’ FROM FILE TOXCENTER; L*** DEL 47 S L4 OR L7; L*** DEL 47 S L4 OR L7; L10 47 SEA FILE=TOXCENTER L9; L11 41 SEA FILE=TOXCENTER L10 NOT MEDLINE/FS D SCAN L11

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS via Chemview
03/2019 | Compound searched: 78-48-8
NTP
03/2019 | “Tributylphosphorotrithioate”; 78-48-8; “Butifos” “Butiphos” “Butyl phosphorotrithioate”; “butyphos” “DEF 6” “DEF Defoliant” “TBPT”; “TBTP” “Tribufos” “Tribuphos” “Tributyl phosphorotrithioate”; “tributyl S, S, S-phosphorotrithioate” “Tributyltrithiophosphate”
Regulations.gov
03/2019 | 78-48-8
NPIRS
03/2019 | 78-48-8
NIH RePORTER
08/2019 | Text Search: “Butifos” OR “Butiphos” OR “Butyl phosphorotrithioate” OR “butyphos” OR “Fosfall” OR “Fos-Fall A” OR “Fossfall” OR “Ortho phosphate defoliant” OR “Phosphorotrithioic acid, S, S, S-tributyl ester” OR “S, S, S-Tributyl phosphorotrithioate” OR “S, S, S-Tributyl trithiophosphate” OR “S, S, S-Tributylphosphorotrithioate” OR “S, S, S-Tributyltrithiophosphate” OR “Tribufos” OR “Tribuphos” OR “Tributyl phosphorotrithioate” OR “tributyl S, S, S-phosphorotrithioate” OR “Tributyl trithiophosphate” OR “Tributylphosphorotrithioate” OR “Tributyltrithiophosphate” OR “TBPT” OR “TBTP” OR “DEF 6” OR “DEF Defoliant” OR “De-Green” OR “E-Z-Off D” OR “Phosphorotrithioic” (Advanced), Search in: Projects Admin IC: All, Fiscal Year: Active Projects
Other | Identified throughout the assessment process

The 2019 results were:

- Number of records identified from PubMed, TOXLINE, and TOXCENTER (after duplicate removal): 67
- Number of records identified from other strategies: 38
- Total number of records to undergo literature screening: 105

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on tribufos:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 105
- Number of studies considered relevant and moved to the next step: 38

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 38
- Number of studies cited in the pre-public draft of the toxicological profile: 132
- Total number of studies cited in the profile: 170

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 March 2019 Literature Search Results and Screen for Tribufos

Description of Figure B-1