# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (_≥_365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102–1, Atlanta, Georgia 30329–4027.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | S,S,S-Tributyl phosphorotrithioate (Tribufos)
CAS Numbers: | 74-48-8
Date: | March 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: Available acute-duration inhalation data were not considered adequate for derivation of an acute-duration inhalation MRL for tribufos.

Rationale for Not Deriving an MRL: No exposure-response human data are available. Available acute-duration inhalation information for tribufos in experimental animals is restricted to a single acute lethality study that reported 4-hour LC_50_ values of 4,650 and 2,460 mg/m^3^ for male and female Sprague-Dawley rats, respectively. This study is inadequate for deriving an acute-duration inhalation MRL for tribufos.

Agency Contacts (Chemical Managers): Rae T. Benedict, Ph.D.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | S,S,S-Tributyl phosphorotrithioate (Tribufos)
CAS Numbers: | 74-48-8
Date: | March 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate
MRL: | 0.04 mg/m^3^
Critical Effect: | Decreased red blood cell acetylcholinesterase (RBC AChE) activity
Reference: | EPA 1992b
Point of Departure: | NOAEL of 2.43 mg/m^3^ (NOAEL_HEC_ of 1.22 mg/m^3^)
Uncertainty Factor: | 30
LSE Graph Key: | 2
Species: | Rat

MRL Summary: An intermediate-duration inhalation MRL of 0.04 mg/m^3^ has been derived for tribufos based on decreased RBC AChE activity among female Wistar rats exposed to tribufos aerosol for 6 hours/day, 5 days/week for 13 weeks (EPA 1992b). The MRL is based on a NOAEL_HEC_ of 1.22 mg/m^3^ and a total uncertainty factor of 30 (3 for extrapolation from animals to humans using dosimetric adjustment and 10 for human variability).

Selection of the Critical Effect: No exposure-response human data are available. Available animal data are restricted to a single well-designed of rats intermittently exposed to tribufos aerosol for 13 weeks (EPA 1992b). In the study, decreased RBC AChE activity was the most sensitive effect of tribufos toxicity.

Selection of the Principal Study: The 13-week inhalation study of Wistar rats (EPA 1992b) is the only available intermediate-duration inhalation study. The study monitored multiple parameters and endpoints and thus was considered adequate in design to serve as basis for deriving an intermediate-duration inhalation MRL for tribufos.

Summary of the Principal Study:

EPA. 1992b. Data evaluation report. Study of the subchronic inhalation toxicity to rats in accordance with OECD guideline No. 413; J. Pauluhn; Bayer AG, FRG; Report No: 102697; June 2, 1992; MRID 423998-01.

Groups of Wistar rats (10/sex/group) were exposed (head-only) to tribufos aerosol (MMAD 1.2–1.3 μm) for 6 hours/day, 5 days/week for 13 weeks at nominal concentrations of 0, 1, 2, 12, or 60 mg/m^3^ (analytically-determined concentrations of 0, 0.93, 2.43, 12.2, and 59.5 mg/m^3^, respectively). Body weights were monitored, and appearance and behavior were evaluated before and after exposure (not during exposure) and on days without exposure. Rectal temperatures were determined for five rats/sex/group monthly immediately following exposure. Blood samples were obtained monthly for hematology and clinical chemistry evaluations. Urine was collected individually during the 12^th^ exposure week for urinalysis. Eye examinations were performed on all rats prior to the first exposure and near the end of the study. Electroretinographic tests were performed on five rats/sex from controls and 59.5 mg/m^3^ groups during week 10 and on five rats/sex from controls and each exposure group prior to terminal sacrifice. At necropsy, selected organs and tissues (adrenals, brain, heart, kidneys, liver, lungs, spleen, thymus, thyroid, ovaries, and testes) were removed and weighed. Histopathological examinations were performed on samples from all major organs and tissues.

The most sensitive effect of repeated inhalation exposure to tribufos was that of decreased RBC AChE activity at various time points during the 13-week study. There were no tribufos exposure-related deaths or signs of morbidity. Three rats were sacrificed or died as a result of nontreatment-related causes. Clinical signs were noted in all rats of the 59.5 mg/m^3^ exposure group and included altered gait, decreased movement, changes in respiration, narrowed eyelids, constricted pupils, piloerection and unpreened coat, aggressive behavior, sensitivity to touch, convulsions with spastic head movements, salivation, exophthalmos (abnormal protrusion of eyeballs), and hypothermia. No clinical signs were observed at lower tribufos exposure levels. There were no exposure-related adverse effects on body weight, hematology, urinalysis, or clinical chemistry assessments, with the exception of RBC and brain AChE activity in males (Table A-1) and females (Table A-2). In male rats, significantly lower RBC AChE activity was observed in the 1 mg/m^3^ exposure group (27% less than controls) at week 0 (but not at other time points) and in the 2.43 mg/m^3^ exposure group (26 and 21% less than controls at exposure weeks 0 and 8, respectively, but not at other time points); these results are considered spurious and not related to tribufos exposure. Significantly decreased RBC AChE activity was noted for all time points (weeks 0, 4, 8, 12, and 13) among 12.2 mg/m^3^ male and female rats (25–65% less than controls) and 59.5 mg/m^3^ (49–91% less than controls). At sacrifice, brain AChE activity among male and female rats was significantly decreased only at the 59.5 mg/m^3^ exposure level (40% less than controls). Treatmentrelated 20–59% RBC AChE inhibition is considered to represent a less serious adverse effect and ≥60% inhibition is considered to represent a serious adverse effect in the absence of more clear indicators of tribufos exposure-related effects. However, at the 59.5 mg/m^3^ exposure level, male and female rats exhibited significantly depressed amplitude of a- and b-waves in electroretinographic testing, which was considered a tribufos-induced adverse effect. Male rats of the 59.5 mg/m^3^ exposure level exhibited significantly increased mean absolute and relative adrenal weight and significantly increased cortical fat deposition in the adrenals (magnitudes not included in the available DER). Minor changes in histology of the nasal and paranasal cavities and lungs were noted across all groups and were considered related to inhalation of vehicle rather than tribufos.

Table A-1 Effect of Tribufos Aerosol on RBC and Brain AChE Activity in Male Wistar Rats Exposed for 6 Hours/Day, 5 Days/Week for 13 Weeks

Exposure parameters | | Mean RBC AChE activity in kU/L (change from controls) | Mean brain AChE activity in U/g (change from controls)
Testing week | Exposure level (mg/m^3^) | Mean RBC AChE activity in kU/L (change from controls) | Mean brain AChE activity in U/g (change from controls)
0 | 0 | 1.44 | NA
0 | 0.93 | 1.05 (−27%)^a^ | NA
0 | 2.43 | 1.06 (−26%)^b^ | NA
0 | 12.2 | 0.92 (−36%)^c^ | NA
0 | 59.5 | 0.63 (−56%)^c^ | NA
4 | 0 | 0.74 | NA
4 | 0.93 | 0.63 (−15%) | NA
4 | 2.43 | 0.64 (−14%) | NA
4 | 12.2 | 0.37 (−50%)^c^ | NA
4 | 59.5 | 0.09 (−88%)^c^ | NA
8 | 0 | 0.78 | NA
8 | 0.93 | 0.69 (−12%) | NA
8 | 2.43 | 0.62 (−21%)^b^ | NA
8 | 12.2 | 0.35 (−55%)^c^ | NA
8 | 59.5 | 0.08 (−90%)^c^ | NA
12 | 0 | 1.18 | NA
12 | 0.93 | 1.15 (−3%) | NA
12 | 2.43 | 1.11 (−6%) | NA
12 | 12.2 | 0.45 (−62%)^c^ | NA
12 | 59.5 | 0.13 (−89%)^c^ | NA
13 | 0 | 0.80 | 12.01
13 | 0.93 | 0.76 (−5%) | 11.78 (−2%)
13 | 2.43 | 0.64 (−20%) | 12.23 (+2%)
13 | 12.2 | 0.28 (−65%)^c^ | 11.78 (−2%)
13 | 59.5 | 0.15 (−81%)^c^ | 7.15 (−40%)^c^

a Not statistically significantly different from control.

b Statistically significantly different from control (p≤0.05), but considered spurious due to lack of significant change at other time points.

c Statistically significantly different from control (p≤0.01).

AChE = acetylcholinesterase; kU = kiloU, where U = a measure of enzymatic activity (1 U = amount of an enzyme that catalyzes the conversion of 1 μmol of substrate per minute); NA = not applicable; RBC = red blood cell

Source: EPA 1992b

Table A-2 Effect of Tribufos Aerosol on RBC and Brain AChE Activity in Female Wistar Rats Exposed for 6 Hours/Day, 5 Days/Week for 13 Weeks

Exposure parameters | | Mean RBC AChE activity in kU/L (change from controls) | Mean brain AChE activity in U/g (change from controls)
Testing week | Exposure level (mg/m^3^) | Mean RBC AChE activity in kU/L (change from controls) | Mean brain AChE activity in U/g (change from controls)
0 | 0 | 1.32 | NA
0 | 0.93 | 1.20 (−9%) | NA
0 | 2.43 | 1.35 (+2%) | NA
0 | 12.2 | 0.99 (−25%)^a^ | NA
0 | 59.5 | 0.67 (−49%)^b^ | NA
4 | 0 | 0.90 | NA
4 | 0.93 | 0.91 (+1%) | NA
4 | 2.43 | 0.96 (+5%) | NA
4 | 12.2 | 0.36 (−60%)^b^ | NA
4 | 59.5 | 0.17 (−81%)b | NA
8 | 0 | 0.62 | NA
8 | 0.93 | 0.65 (+5%) | NA
8 | 2.43 | 0.69 (+11%) | NA
8 | 12.2 | 0.32 (−48%)^b^ | NA
8 | 59.5 | 0.07 (−89%)^b^ | NA
12 | 0 | 1.09 | NA
12 | 0.93 | 1.10 (+1%) | NA
12 | 2.43 | 1.14 (+5%) | NA
12 | 12.2 | 0.41 (−62%)^a^ | NA
12 | 59.5 | 0.10 (−91%)^b^ | NA
13 | 0 | 0.92 | 11.69
13 | 0.93 | 0.93 (+1%) | 11.87 (+2%)
13 | 2.43 | 0.81 (−12%) | 11.64 (−0%)
13 | 12.2 | 0.33 (−64%)^b^ | 11.45 (−2%)
13 | 59.5 | 0.12 (−87%)^b^ | 6.99 (−40%)^b^

a Statistically significantly different from control (p≤0.05).

b Statistically significantly different from control (p≤0.01).

AChE = acetylcholinesterase; kU = kiloU, where U = a measure of enzymatic activity (1 U = amount of an enzyme that catalyzes the conversion of 1 μmol of substrate per minute); NA = not applicable; RBC = red blood cell

Source: EPA 1992b

Selection of the Point of Departure for the MRL: The most sensitive effect of repeated inhalation exposure to tribufos was that of decreased RBC AChE activity at various time points during the 13-week study. Benchmark dose (BMD) analysis of the critical effect dataset (RBC AChE activity) was performed on the datasets for RBC AChE activity in the male and female rats at the 13-week timepoint. Although the publicly-available DER (EPA 1992b) of the unpublished study included only mean values for RBC AChE activity without a measure of variance, standard deviation values were reported in the unpublished study (MRID42399801). All available continuous variable models in EPA’s Benchmark Dose Software (BMDS, Version 3.1.1) were fit to the data for RBC AChE activity in the male and female rats separately using a benchmark response (BMR) of 20% change from controls.

None of the models provided adequate fit to the modeled variance (p<0.05) for males or females using either constant or nonconstant variance. Therefore, a BMD approach to deriving an intermediate-duration inhalation MRL was not used. However, an intermediate-duration inhalation MRL for tribufos can be derived using a NOAEL/LOAEL approach. The principal study identified a NOAEL of 2.43 mg/m^3^ and a serious LOAEL of 12.2 mg/m^3^ for >60% decreased RBC AChE activity in male and female Wistar rats. The NOAEL (2.43 mg/m^3^) serves as the point of departure (POD) for deriving an intermediate-duration inhalation MRL for tribufos.

Adjustment for Intermittent Exposure: The NOAEL of 2.43 mg/m^3^ was adjusted from intermittent to continuous exposure as follows:

NOAEL_ADJ_ = 2.43 mg / m^3^ × 6 hours / 24 hours × 5 days / 7 days = 0.43 mg / m^3^

Human Equivalent Concentration: A regional deposited dose ratio (RDDR_ER_) of 2.839 for extrarespiratory effects (RBC AChE inhibition) in female Wistar rats (slightly lower than the RDDR_ER_ of 2.926 for the males and therefore considered slightly more protective) was used to extrapolate from rats to humans. The RDDR_ER_ was calculated using EPA’s software (Version 2.3) (EPA 1994) for calculating RDDRs and the parameters listed in Table A-3.

Table A-3 Parameters^a^ Used to Calculate the Regional Deposited Dose Ratio (RDDR_ER_) for Tribufos-induced Extrarespiratory Effects Using EPA’s Software (Version 2.3) and RDDR_ER_ Values for Male and Female Wistar Rats

Biological parameters^b^ | Wistar rat | | Human
Biological parameters^b^ | Male | Female | Human
Surface area
Extrathoracic | 15 cm^2^ | 15 cm^2^ | 200 cm^2^
Tracheobronchial | 22.5 cm^2^ | 22.5 cm^2^ | 3,200 cm^2^
Pulmonary | 0.34 m^2^ | 0.34 m^2^ | 54 m^2^
Minute ventilation | 122.1 mL | 160.1 | 147.24 mL
Body weight | 217 g | 156 g | 70 kg
RDDR_ER_ | 2.926 | 2.839 | –

a Mass median aerodynamic diameter (MMAD) =1.2 μm; geometric standard deviation =1.4 μm (EPA 1992b).

b Parameters are default values for rats and humans from the U.S. Environmental Protection Agency (EPA) software, except for default subchronic body weights for male and female Wistar rats (EPA 1988) because quantitative body weight data were not included in the available DER (EPA 1992b).

Source: EPA 1992b

The human equivalent concentration was calculated using Equation 4-5 (EPA 1994) as follows:

NOAEL_HEC_ = NOAEL_ADJ_ × RDDR_ER_ = 0.43 mg / m^3^ × 2.839 = 1.22 mg / m^3^

Uncertainty Factor: The NOAEL_HEC_ of 1.22 mg/m^3^ was divided by a total uncertainty factor of 30:

- 3 for extrapolation from animals to humans using dosimetric adjustment
- 10 for human variability

MRL = NOAEL_HEC_ ÷ uncertainty factors 1.22 mg / m^3^ ÷ (3 × 10) = 0.04 mg / m^3^

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Available animal studies that evaluated the effects of intermediate-duration oral exposure to tribufos identified decreased RBC AChE activity as the most sensitive effect of tribufos toxicity (Astroff et al. 1998; CalEPA 2004; EPA 1991b, 1992c, 2005a, 2013).

Agency Contacts (Chemical Managers): Rae T. Benedict, Ph.D.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | S,S,S-Tributyl phosphorotrithioate (Tribufos)
CAS Numbers: | 74-48-8
Date: | March 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: No human or animal data were located regarding health effects from chronic-duration inhalation exposure to tribufos.

Rationale for Not Deriving an MRL: No chronic-duration inhalation data are available.

Agency Contacts (Chemical Managers): Rae T. Benedict, Ph.D.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | S,S,S-Tributyl phosphorotrithioate (Tribufos)
CAS Numbers: | 74-48-8
Date: | March 2020
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: Available acute-duration oral data were not considered adequate for derivation of an acute-duration inhalation MRL for tribufos.

Rationale for Not Deriving an MRL: No human data are available. Acute-duration oral animal studies evaluated body weight, clinical signs, AChE activity, reproductive, and/or developmental endpoints (Astroff and Young 1998; EPA 1990b, 1990c, 2012a, 2012b, 2012c, 2012d, 2012e, 2012f). The lowest LOAEL for tribufos-mediated body weight effects was 9 mg/kg/day in a rabbit study (EPA 1990c). NOAELs for developmental endpoints in rat and rabbit studies ranged from 7 to 28 mg/kg/day (Astroff and Young 1998; EPA 1990b, 1990c, 2012f). Collectively, the acute-duration oral studies identified decreased RBC AChE activity as the most sensitive tribufos-mediated effect from acute-duration oral exposure. Table A-4 summarizes NOAELs and LOAELs for tribufos-mediated effects on RBC AChE activity following intermediate-duration oral exposure. The rabbit study (EPA 1990c) identified the lowest LOAEL (1 mg/kg/day) for tribufos-induced RBC AChE inhibition. The effect occurred at the lowest dose tested and represented a serious effect (>60% RBC AChE inhibition). ATSDR does not derive an MRL based on a serious LOAEL in the absence of an identified NOAEL. Results from available rat studies were not considered appropriate PODs for deriving an acute-duration oral MRL for tribufos because they identified LOAELs at doses ≥5 times higher than the serious LOAEL from the rabbit study in the absence of NOAELs. Therefore, ATSDR elected not to derive an acute-duration oral MRL for tribufos.

Table A-4 NOAELs and LOAELs for RBC AChE Inhibition Following Acute-Duration Oral Exposure to Tribufos

Study design (doses in mg/kg/day) | Dose (RBC AChE % inhibition) | | | Reference
Study design (doses in mg/kg/day) | NOAEL^a^ | LOAEL^b^ | Serious LOAEL^c^ | Reference
Young adult female Sprague-Dawley rats; GO, 1 time (0, 80) | ND | ND | 80 (up to 90%) | EPA 2012c
Young adult female Sprague-Dawley rats; GO, 1 time (0, 2, 10, 80) | 10 | ND | 80 (74%) | EPA 2012d
11-Day-old Sprague-Dawley rat pups; GO, 1 time (0, 50) | M: ND; F: ND | M: ND; F: ND | M: 50 (90%); F: 50 (92%) | EPA 2012b
11-Day-old Sprague-Dawley rat pups; GO, 1 time (0, 20, 40, 50) | M: ND; F: ND | M: 20 (59%); F: ND | M: 40 (76%); F: 20 (71%) | EPA 2012a
11-Day-old Sprague-Dawley rat pups; GO, 1 time (0, 2, 10, 50) | M: 2; F: ND | M: 10 (47%); F: 2 (27%) | M: 50 (86%); F: 50 (89%) | EPA 2012d
Young adult female Sprague-Dawley rats; GO, 1 time/day, 11 days (0, 0.1, 1, 5) | 1 | ND | 5 (64%) | EPA 2012e
11-Day-old Sprague-Dawley rat pups; GO, 1 time/day, 11 days (0, 0.1, 1, 5) | M: 1; F: 1 | M: ND; F: ND | M: 5 (66%); F: 5 (69%) | EPA 2012e
11-Day-old Sprague-Dawley rat pups; GO, 1 time/day, 11 days (0, 5, 10, 15, 20) | M: ND; F: ND | M: 5 (49%); F: 5 (36%) | M: 15 (83%); M: 15 (66%) | EPA 2012a
Pregnant Sprague-Dawley rats, G, 1 time/day, GDs 6–15 (0, 1, 7, 28) | 1 | ND | 7 (71%) | Astroff and Young 1998; EPA 1990b
Pregnant Sprague-Dawley rats GO, 1 time/day; GDs 6–19 (0, 0.3–0.8, 7, 28) | 0.3^d^ | ND | 7 (75%) | EPA 2012f
Pregnant American Dutch rabbits; G, 1 time/day, GDs 7–19 (0, 1, 3, 9) | ND | ND | 1 (70%) | EPA 1990c

a <20% decrease in RBC and/or brain AChE represents a NOAEL.

b 20–59% decrease in RBC and/or brain AChE activity represents a less serious adverse effect.

c ≥60% decrease in RBC and/or brain AChE activity represents a serious adverse effect.

d Low test substance concentrations measured in the 1 mg/kg/day dose group resulted in estimated time-weighted average dosing in the range of 0.3–0.8 mg/kg/day; using a conservative approach, the lowest dose in the range is considered the NOAEL.

AChE = acetylcholinesterase; F = females; G = gavage; GD = gestation day; GO = gavage in oil; LOAEL = lowest-observed-adverse-effect level; M = males; ND = not determined; NOAEL = no-observed-adverse-effect level; RBC = red blood cell

Agency Contacts (Chemical Managers): Rae T. Benedict, Ph.D.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | S,S,S-Tributyl phosphorotrithioate (Tribufos)
CAS Numbers: | 74-48-8
Date: | March 2020
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.003 mg/kg/day
Critical Effect: | Decreased red blood cell acetylcholinesterase (RBC AChE) activity
Reference: | Astroff et al. 1998; EPA 1992c
Point of Departure: | NOAEL of 0.28 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 14
Species: | Rat

MRL Summary: An intermediate-duration oral MRL of 0.003 mg/kg/day has been derived for tribufos based on decreased RBC AChE activity in Sprague-Dawley rats administered tribufos in the diet in a 2-generation toxicity study (Astroff et al. 1998; EPA 1992c). The MRL is based on a NOAEL of 0.28 mg/kg/day and a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: Potential candidate critical effects for deriving an intermediate-duration oral MRL for tribufos are summarized in Table A-5. Quantitative data were not available for the reported hematological effects in the rat study summarized by CalEPA (2004) and EPA (1992d). Therefore, the neurological effect (tribufos-mediated decreased RBC AChE activity) was selected as the critical effect for deriving an intermediate-duration oral MRL for tribufos.

Table A-5 Summary of Potential Candidate Critical Effects for Deriving an Intermediate-Duration Oral MRL for Tribufos from Dietary Studies

Species | Duration | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Hematological effects
Fischer 344 rat | 3- and 6-month evaluations in 2-year study | 0.2 M; 0.2 F | 1.8 M; 2.3 F | Decreases in RBC count, hemoglobin, hematocrit (quantitative data not available) | CalEPA 2004; EPA 1992d
Neurological effects
Sprague-Dawley rat | 2 generations (premating-lactation) | F0 M: 0.28; F0 F: 0.31 | F0 M: 2.00; F0 F: 2.25 | 35 and 37% decreased RBC AChE activity in F0 males and females, respectively, during premating | Astroff et al. 1998; EPA 1992c
Han Wistar rat | 4 weeks | 0.43 | 4.32 | 66% decreased RBC AChE activity (serious LOAEL) | EPA 2013
Wistar rat | 42 days (GD 0–LD 21) | 0.4 | 3.4 | 76% decreased RBC AChE activity (serious LOAEL) | EPA 2005a
CD-1 mouse | 8 weeks | 3.4 M; 5.6 F | 9.4 M; 14.3 F | 37 and 44% decreased RBC AChE activity in males and females, respectively | CalEPA 2004
Beagle dog | 364 days | 0.4 M; 0.4 F | 1.7 M; 2.0 F | 24 and 29% decreased RBC AChE activity in males and females, respectively | EPA 1991b

AChE = acetyl cholinesterase; F = female(s); GD = gestation day; LD = lactation day; LOAEL = lowest observed adverse effect level; M = male(s); NOAEL = no-observed-adverse-effect level; RBC = red blood cells

Selection of the Principal Study: The 364-day dietary study in dogs (CalEPA 2004; EPA 1991b) and the 2-generation dietary study in rats (Astroff et al. 1998; EPA 1992c) identified similar LOAEL values (1.7 mg/kg/day for male dogs versus 2.0 and 2.09 mg/kg/day for the F0 and F1 male rats, respectively).

The NOAEL for the F0 and F1 male rats (0.28 mg/kg/day) was slightly lower than the NOAELs for the F0 and F1 female rats (0.31 mg/kg/day) and the male dogs (0.4 mg/kg/day). Furthermore, the rat study employed more animals per dose group than the dog study (10 rats/sex/dose versus 4 dogs/sex/dose). Therefore, the 2-generation rat study was selected as the principal study for deriving an intermediate-duration oral MRL for tribufos.

Summary of the Principal Study:

Astroff AB, Freshwater KJ, Eigenberg DA. 1998. Comparative organophosphate-induced effects observed in adult and neonatal Sprague-Dawley rats during the conduct of multigeneration toxicity studies. Reprod Toxicol 12(6):619–645.9875697

EPA. 1992c. A two-generation dietary reproduction study in rats using tribufos (DEF). D.A. Eigenberg, Mobay, Corporate Toxicology Department, study number 88-971-AK; Sept 10, 1991. MRID 420401-01. Memorandum. Tribufos (DEF) reproduction studies. U.S. Environmental Protection Agency.

Groups of Sprague-Dawley rats (30/sex/group) were administered tribufos in the diet for 10 weeks prior to mating and up to 21 or 28 days of mating, and throughout 3 weeks of gestation (F0 males and females) and 3 weeks of lactation (F0 females) at concentrations of 0, 4, 32, or 260 ppm. Groups of F1 offspring (30/sex/group) were continued on the same treatment schedule as their parents to produce F2 weanlings. Parental rats were monitored for clinical signs, body weight, and food consumption. Estrous cyclicity was evaluated in selected female parental rats. At sacrifice (F0 and F1 parental males following delivery of F1 and F2 litters, respectively; F0 and F1 parental females at F1 and F2 pup weaning, respectively), parental rats were subjected to comprehensive gross pathological examination; histopathological examinations were performed on reproductive organs and tissues, pituitary, and gross lesions. Plasma ChE and RBC AChE activities were determined from 10 parental rats/sex from each generation at 56 days (F0) and 62 days (F1) of premating tribufos treatment and again at terminal sacrifice, at which time brain tissue was removed and processed for brain AChE activity determination. F1 pups surviving to lactation day 21 and all F2 pups were monitored periodically for body weight during the lactation period. F1 litters were culled to four pups/litter on lactation day 4. Plasma ChE activity and RBC and brain AChE activities were determined for one F1 and one F2 pup of each sex from each of 10 litters at lactation days 4 and 21. Selected reproductive endpoints, fertility, and fetal and pup viability were evaluated.

The study authors calculated tribufos doses (reported in Astroff et al. 1998) based on dietary concentrations, food intake, and body weight data. At dietary concentrations of 4, 32, and 260 ppm, author-calculated tribufos doses to F0 parental rats were 0.28, 2.0, and 17.6 mg/kg/day, respectively, for the males and 0.31, 2.25, and 20.04 mg/kg/day, respectively, for the females during pre-mating treatment. Calculated doses to dams were 0.27, 2.03, and 18.07 mg/kg/day, respectively, during gestation and 0.81, 6.13, and 42.23 mg/kg/day, respectively, during lactation. Author-calculated tribufos doses to F1 parental rats were 0.28, 2.09, and 20.63 mg/kg/day, respectively, for the males, and 0.31, 2.40, and 22.93 mg/kg/day, respectively, for the females during pre-mating treatment. Calculated doses to the F1 dams were 0.28, 2.08, and 19.03 mg/kg/day, respectively, during gestation and 0.84, 6.77, and 49.61 mg/kg/day, respectively, during lactation.

There were no remarkable clinical signs or gross or histopathologic findings among adults or pups of either generation. Body weight was not affected in male or female F0 parental rats during the premating phase. Gestational body weight of high-dose F0 dams was 7% lower than that of controls on GD 20; maternal body weight was decreased by 8–12% throughout the lactation period and was accompanied by decreased maternal food consumption (approximately 20% less than that of controls). Significantly lower mean body weights were observed in high-dose F1 parental rats during the 10-week pre-mating phase (quantitative data for F1 males were not presented in the available DER). The high-dose F1 dams exhibited approximately 25% lower mean body weight than controls at the beginning of the pre-mating phase, which decreased in magnitude to approximately 8% less than controls at the end of the pre-mating period. During gestation, the high-dose mean maternal body weight was significantly lower (approximately 6% less than that of controls) only at the end of gestation. During lactation, the high-dose F1 dam mean body weight was significantly less (approximately 10%) than that of controls at all time periods and was accompanied by significantly decreased maternal food consumption during lactation weeks 2 and 3 (magnitude not specified; however, appears to have been approximately 10%). High-dose F1 pup mean body weight ranged from 11% lower than that of controls on lactation day 0 to 21–30% lower on lactation days 4–21, which may reflect decreased gestational body weight and decreased food consumption of the high-dose parental dams during lactation. High-dose F1 pup mean body weight gain during lactation was 32% less than that of controls. High-dose F2 pup mean body weight was significantly less (approximately 14–22%) than that of controls during lactation days 7–21, which may reflect, in part, decreased gestational body weight, decreased food consumption of the high-dose parental F1 dams during lactation, and/or decreased quality of rat milk produced during lactation. High-dose F2 pup mean body weight gain during lactation was approximately 25% less than that of controls.

The high-dose F0 dams exhibited significantly lower indices for gestation, birth, viability, and lactation. Mean litter size was significantly lower than that of controls. The high-dose F1 dams exhibited significantly lower indices for birth, viability, and lactation. The significant effects on reproduction, fertility, and pup viability and body weight occurred at a dose level resulting in significantly lower mean body weight and food consumption among the F0 dams during gestation and lactation and the F1 dams from pre-mating through lactation.

Decreased plasma ChE activity was observed in low-dose F0 females, mid-dose F0 males and females and F1 parental females, and high-dose F0 and F1 parental males and females. Among pups, effects on plasma ChE were limited to mid- and high-dose F1 male and female pups, mid- and high-dose F2 male pups, and high-dose F2 female pups.

Mid- and high-dose F0 and F1 parental rats exhibited significantly decreased RBC AChE activity (26–53% less than that of controls). At terminal sacrifice, significantly decreased brain AChE activity (29–35% less than that of controls) was noted in mid-dose F0 and F1 parental rats. At the high-dose level, brain AChE activity was decreased by 33–35% in F0 and F1 parental males and by 80% in F0 and F1 parental females. Toxicologically significant decreases in pup AChE activity were restricted to high-dose groups at sacrifice on lactation day 21 and included 24% decreased RBC AChE activity in F2 males and 23 and 38% decreased RBC AChE activity in high-dose F1 and F2 females, respectively.

Selection of the Point of Departure for the MRL: The dataset for the F0 male rats was considered preferable to the dataset for the F1 male rats because it represented the greatest magnitude of RBC AChE inhibition at the lowest LOAEL (35% inhibition at 2.0 mg/kg/day for F0 males versus 26% inhibition at 2.09 mg/kg/day for the F1 males). A BMD modeling approach was considered to identify a potential POD for deriving an intermediate-duration oral MRL for tribufos based on the results from the F0 male rats of the 2-generation study. For BMD analysis, mean RBC AChE activity data (Table A-6) were fit to continuous models in EPA’s BMDS (version 3.1.1) using a BMR of 20% decrease from control. The following procedure for fitting continuous data was used. Adequate model fit was judged by three criteria: χ^2^ goodness-of-fit p-value (p≥0.1), visual inspection of the dose-response curve, and scaled residual (>−2 and <+2) at the data point (except the control) closest to the predefined BMR. Among models providing adequate fit to the data, the lowest BMDL was selected as the POD when the difference between the BMDLs estimated from these models was >3-fold; otherwise, the BMDL from the model with the lowest Akaike’s Information Criterion (AIC) was chosen.

Table A-6 Day 56 RBC AChE Activity in F0 Male Sprague-Dawley Rats Administered Tribufos in the Diet from 10 Weeks Prior to Mating to Delivery of F1 Pups

Concentration in food (ppm) | 0 | 4 | 32 | 260
Dose (mg/kg/day) | 0 | 0.28 | 2 | 17.6
Number of rats | 10 | 10 | 10 | 10
Mean RBC AChE activity (IU/mL) | 2.85 | 2.83 | 1.96^a^ | 1.35^a^
Standard deviation | 0.16 | 0.17 | 0.09 | 0.04

a Significantly different from control (p<0.05).

AChE = acetylcholinesterase; RBC = red blood cell

Source: Astroff et al. 1998; EPA 1992c

BMD analysis of the datasets for the F0 male rats from the 2-generation dietary study (Astroff et al. 1998; EPA 1992c) resulted in inadequate fit using either constant variance or nonconstant variance. Therefore, a NOAEL/LOAEL approach was applied to derive an intermediate-duration oral MRL for tribufos. The NOAEL of 0.28 mg/kg/day for the F0 male rats was selected as the POD.

Adjustment for Intermittent Exposure: Not applicable

Uncertainty Factor: The NOAEL of 0.28 mg/kg/day was divided by a total uncertainty factor of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = NOAEL ÷ uncertainty factors 0.28 mg / kg / day ÷ (10 × 10) = 0.003 mg / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: The selection of the NOAEL of 0.28 mg/kg/day for F0 male rats of the principal study (Astroff et al. 1998; EPA 1992c) as basis for an intermediate-duration oral MRL for tribufos is supported by results from several studies (Table A-5).

Agency Contacts (Chemical Managers): Rae T. Benedict, Ph.D.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | S,S,S-Tributyl phosphorotrithioate (Tribufos)
CAS Numbers: | 74-48-8
Date: | March 2020
Profile Status: | Final
Route: | Oral
Duration: | Chronic
MRL: | 0.0005 mg/kg/day
Critical Effect: | Vacuolar degeneration in small intestines
Reference: | CalEPA 2004; EPA 1992d
Point of Departure: | BMDL_10_ of 0.05 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 20
Species: | Rat

MRL Summary: A chronic-duration oral MRL of 0.0005 mg/kg/day has been derived for tribufos based on vacuolar degeneration in the small intestines of Fischer 344 rats administered tribufos in the diet for 2 years (CalEPA 2004; EPA 1992d). The MRL is based on a BMDL_10_ of 0.05 mg/kg/day and a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: Chronic-duration oral studies of mice and rats identified tribufos-mediated effects on red blood cell acetylcholinesterase (RBC AChE) activity and nonneoplastic lesions in the small intestine as the most sensitive effects. Table A-7 summarizes NOAELs and LOAELs for these tribufos-mediated effects. Based on NOAELs and LOAELs, rats appear to be more sensitive than mice to tribufos toxicity following oral exposure. Therefore, the rat data were considered the more appropriate species for consideration of MRL derivation. In the rat study, the lowest LOAEL is 1.8 mg/kg/day for tribufos-induced RBC AChE inhibition and for histopathologic lesions in the small intestines. Therefore, tribufos-mediated histopathologic intestinal lesions and RBC AChE inhibition in the rats were initially selected to represent critical effects for deriving a chronic-duration oral MRL for tribufos. Although selected hematological values in the 1.8 mg/kg/day dose group of rats were significantly different from those of controls at interim evaluation, at least some values had returned to normal at 2 years. Therefore, hematological changes were not considered as a basis for MRL derivation.

Table A-7 NOAELs and LOAELs for RBC AChE Activity and Incidences of Nonneoplastic Lesions in the Small Intestine of Rats and Mice Following Chronic-Duration Oral Exposure to Tribufos

Effect Species (duration) | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Reference
Decreased RBC AChE activity
Mouse (90 weeks) | | | CalEPA 2004; EPA 1990a
Males | 1.5 | 8.4
Females | 2.0 | 11.3
Rat (2 years) | | | CalEPA 2004; EPA 1992d
Males | 0.2 | 1.8
Females | 0.2 | 2.3
Vacuolar degeneration in small intestine
Mouse (90 weeks) | | | CalEPA 2004; EPA 1990a
Males | 1.5 | 8.4
Females | 2.0 | 11.3
Rat (1-year interim sacrifice) | | | CalEPA 2004; EPA 1992d
Males | 0.2 | 1.8
Females | 0.2 | 2.3
Hyperplasia in small intestine
Rat (2-year terminal sacrifice) | | | CalEPA 2004; EPA 1992d
Males | 0.2 | 1.8
Females | 0.2 | 2.3

AChE = acetylcholinesterase; LOAEL = lowest-observed-adverse-effect level; M = males; NOAEL = no-observed-adverse-effect level; RBC = red blood cell

Selection of the Principal Study: Available animal studies include a 90-week dietary study of CD-1 mice (CalEPA 2004; EPA 1990a) and a 2-year dietary study of Fischer 344 rats (CalEPA 2004; EPA 1992d). The mouse study (CalEPA 2004; EPA 1990a) identified NOAELs of 1.5 and 2.0 mg/kg/day for males and females, respectively, and LOAELs of 8.4 and 11.3 mg/kg/day for males and females, respectively, based on decreased RBC AChE activity (>20% less than respective controls) and significantly increased incidences of vacuolar degeneration in the small intestine (males and females) and extramedullary hematopoiesis in the spleen (males). The NOAELs and LOAELs from the mouse study (CalEPA 2004; EPA 1990a) are higher than those identified in the rat study (CalEPA 2004; EPA 1992d) that identified a NOAEL of 0.2 mg/kg/day (males and females) and LOAELs of 1.8 and 2.3 mg/kg/day (males and females, respectively) for >20% RBC AChE inhibition and increased incidences of histopathologic lesions (vacuolar degeneration and hyperplasia) in the small intestine. Therefore, the rat study (CalEPA 2004; EPA 1992d) was selected as the principal study for deriving a chronic-duration oral MRL for tribufos.

Summary of the Principal Study:

CalEPA. 2004. S,S,S-Tributyl phosphorotrithioate (tribufos) risk characterization document (Revision No. 1). California Environmental Protection Agency, Department of Pesticide Regulation. www.cdpr.ca.gov/docs/risk/rcd/def_r1.pdf.

EPA. 1992d. Memorandum: Tribufos (DEF), rat combined chronic/oncogenicity study. Technical grade tribufos (DEF): A chronic feeding study in the Fischer 344 rat, W.R. Christenson, Miles Inc. Study No. 88-271-AA, Report # 102675, May 1, 1992. MRID 423351-01. U.S. Environmental Protection Agency.

Groups of Fischer 344 rats (50/sex/dose) were administered tribufos in the diet for 2 years at nominal concentrations of 0, 4, 40, or 320 ppm (recovery from food was 96.5%) (CalEPA 2004; EPA 1992d). CalEPA (2004) reported mean tribufos doses as 0, 0.2, 1.8, and 16.8 mg/kg/day, respectively, for the males and 0, 0.2, 2.3, and 21.1 mg/kg/day, respectively, for the females. Other groups of rats (10 or 20/sex/group) were included for interim sacrifice at 12 months. Still other rats (20/sex/group) were included for 12- and 24-month histopathologic evaluation of brain, spinal cord, sciatic nerves and their branches, and eyes and optic nerves. Rats were monitored for survival, clinical signs, body weight, and food intake. Ophthalmologic examinations were performed at the start of dosing and just prior to terminal sacrifice. Electroretinographic examinations were performed on selected 2-year animals and all surviving 2-year neurotoxicity animals just prior to terminal sacrifice. Blood was collected from 20 rats/sex/group at 3, 6, 12, 18, and 24 months on study for hematological and clinical chemistry evaluation (including plasma ChE and RBC AChE activity); where possible, the same rats were used at each time interval. Determination of brain AChE activity was made at terminal sacrifice. Urine was collected for urinalysis (collection time schedule not specified in available study summaries). Gross pathological examinations were performed on all rats at termination. Organs and tissues weighed were adrenals, brain, heart, kidneys, liver, lungs, spleen, testes, ovaries, and thymus. Tissues were collected and processed for histopathological examination.

The high-dose rats exhibited increased incidences of pale eyes, ocular opacity, rough coats, rash, raised zones on the skin, urine stains, clear discharge, soft feces, and diarrhea (CalEPA 2004). A slight (but not statistically significant) decrease in survival was observed in both sexes of high-dose rats. Both sexes of high-dose rats exhibited slightly increased mean food consumption, but approximately 15% depressed mean body weight gain.

There were no signs of treatment-related ocular effects at 12-month interim evaluation. At 24-month examination, the high-dose rats exhibited significantly increased incidences of cataracts, corneal opacity, corneal neovascularization, and iritis and/or uveitis. High-dose females also exhibited significantly increased incidence of lens opacity. High-dose male and female rats exhibited high rates of bilateral unrecordable (flat) responses in the electroretinographic tests; significantly increased incidences of bilateral retinal atrophy were noted in high-dose rats at 1-year sacrifice and 2-year sacrifice. Significantly increased incidences of optic nerve atrophy were noted in high-dose rats at 2-year sacrifice. Histopathologic examination of the eye at 2 years confirmed uveitis, cataract, and neovascularization in the high-dose males and females.

Mid- and high-dose rats exhibited significant decreases in RBC counts, hemoglobin, and hematocrit at 6 and 12 months, but some of these values had returned to normal by 18 and 24 months. At terminal sacrifice, significant increases in RBC count and hematocrit were noted in high-dose males and significant increases in hemoglobin and hematocrit were observed in high-dose females, indicating the possible involvement of some compensatory mechanism. The low-dose treatment level was considered a NOAEL for hematological effects and the mid-dose level a LOAEL.

At 6-month evaluation, mid- and high-dose groups exhibited decreases in plasma glucose, cholesterol, aspartate aminotransferase (AST), alanine aminotransferase (ALT), alkaline phosphatase, total protein, albumin, and globulin; and increases in blood urea nitrogen (BUN), triglycerides, and creatine kinase. By 24-month evaluation, some of these values had returned to control levels (AST, ALT, creatine kinase, and triglycerides) in mid- and high-dose groups. Other values (total protein, albumin, globulin, and BUN) returned to control levels only in the mid-dose rats. The toxicological significance of the changes in clinical chemistry is questionable in the absence of histopathological changes in liver, kidney, or heart. Urinalysis revealed no apparent treatment-related effects.

At study termination, mean plasma ChE activity was significantly decreased at all dose levels (16 and 6% lower in low-dose males and females, respectively; 56 and 60% lower in mid-dose males and females, respectively; 80 and 83% lower in high-dose males and females, respectively). Mean RBC AChE activity was significantly decreased in mid- and high-dose groups (27 and 28% lower in mid-dose males and females, respectively; 48 and 47% lower in high-dose males and females, respectively). Brain AChE activity was significantly decreased only at the high-dose level (60 and 68% lower in males and females, respectively).

Gross pathologic examinations revealed abnormal consistency and discoloration in the small intestine of both sexes at mid- and high-dose levels, enlarged adrenals in high-dose males and females, and ocular opacity in high-dose males. Mid- and high-dose groups of male and female rats exhibited increased incidences of histopathologic lesions in the small intestines (vacuolar degeneration and hyperplasia) at 1-year interim sacrifice and 2-year terminal sacrifice (Table A-7). The lesions in the small intestine accompanied gross findings of abnormal consistency and discoloration. Significantly increased incidences of vacuolar degeneration were noted in adrenal glands from high-dose rats (35/49 males versus 6/50 controls; 41/50 females versus 10/50 controls). This lesion was accompanied by gross pathology (enlarged adrenals) and significantly increased adrenal weight. There was no evidence of dose-related increased incidences of histopathologic lesions in the brain, spinal cord, or sciatic nerve and no indications of treatment-related increased incidences of benign or malignant tumors at any site. The study identified a NOAEL of 0.2 mg/kg/day (males and females) and LOAELs of 1.8 mg/kg/day (males) and 2.3 mg/kg/day (females) for 27–28% decreased RBC AChE activity and increased incidences of nonneoplastic lesions in the small intestine. Changes in selected hematology parameters, observed in mid- and high-dose rats at 3-, 6-, and 12-month interim evaluations, had at least partially returned to normal by terminal sacrifice.

Selection of the Point of Departure for the MRL: As shown in Table A-7, RBC AChE inhibition and histopathologic lesions (vacuolar degeneration and hyperplasia) in the small intestines in the 2-year rat study represent the lowest LOAEL (1.8 mg/kg/day) for adverse effects among available study results. BMD analysis is preferable to a NOAEL/LOAEL approach for identifying an appropriate point of departure for MRL derivation. The datasets for vacuolar degeneration and for hyperplasia in the small intestines of the rats are amenable to BMD analysis. BMD analysis of the dataset for RBC AChE inhibition is precluded by lack of mean RBC AChE activity and variance data in publicly-available summaries (CalEPA 2004; EPA 1992d) of the unpublished study.

Incidence data for vacuolar degeneration at 1- and 2-year sacrifice and for hyperplasia at 2-year sacrifice (Table A-8) were fit to all dichotomous models in EPA’s BMDS (version 3.1.1) using a BMR of 10% change from control incidence. Adequate model fit was judged by three criteria: chi-square goodness-off-it p-value (p≥0.1), visual inspection of the dose-response curve, and scaled residual (>−2 and <+2) at the data point (except the control) closest to the predefined BMR. Among models providing adequate fit to the data, the lowest BMDL_10_ was selected as the POD when the difference between the BMDLs estimated from these models was >3 fold; otherwise, the BMDL_10_ from the model with the lowest Akaike’s Information Criterion (AIC) was chosen.

Table A-8 Incidence Data for Selected Nonneoplastic Lesions in the Small Intestine of Male and Female Fischer 344 Rats Administered Tribufos in the Diet for 1 Year (Interim Sacrifice) or 2 Years (Terminal Sacrifice)

| | Interim sacrifice (1 year) | Terminal sacrifice (2 years)
Exposure level (ppm) | Estimated dose (mg/kg/day) | Vacuolar degeneration | Hyperplasia | Vacuolar degeneration
Males
0 | 0 | 0/20 (0%) | 0/50 (0%) | 0/50 (0%)
4 | 0.2 | 0/10 (2%) | 3/50 (6%) | 1/50 (2%)
40 | 1.8 | 7/10^a^ (70%) | 23/50^a^ (46%) | 24/50^a^ (48%)
320 | 16.8 | 18/20^a^ (90%) | 34/50^a^ (68%) | 37/50^a^ (74%)
Females
0 | 0 | 0/20 (0%) | 1/50 (2%) | 0/50 (0%)
4 | 0.2 | 0/10 (0%) | 0/50 (0%) | 0/50 (0%)
40 | 2.3 | 8/10^a^ (80%) | 11/50^b^ (22%) | 19/50^a^ (38%)
320 | 21.1 | 16/20^a^ (80%) | 30/50^a^ (60%) | 35/50^a^ (70%)

a Significantly different from control according to Fisher’s exact test (p<0.001).

b Significantly different from control according to Fisher’s exact test (p<0.01).

Source: CalEPA 2004

The Loglogistic, Logprobit, and dichotomous Hill models provided adequate fit to the data for vacuolar degeneration in the male rats at 1-year interim sacrifice (Table A-9); the Logprobit model was selected as the best-fitting model (lowest BMDL_10_). BMD analysis of small intestine vacuolar degeneration in the male rats at 2-year terminal sacrifice resulted in inadequate fit to the data. The Logprobit model provided adequate fit to the data for hyperplasia in the male rats at 2-year terminal sacrifice (Table A-10).

The dichotomous Hill model provided adequate fit to the data for vacuolar degeneration in the female rats at 1-year interim sacrifice (Table A-11). The Loglogistic and Logprobit models provided adequate fit to the data for vacuolar degeneration (Table A-12) in the small intestine of the female rats at 2-year terminal sacrifice; the Logprobit model was selected as the best-fitting model (lowest AIC). The Loglogistic and Logprobit models provided adequate fit to the data for hyperplasia (Table A-13) in the small intestine of the female rats at 2-year terminal sacrifice; the Loglogistic model was selected as the best-fitting model (lowest AIC).

Table A-9 Results from BMD Analysis of Incidences of Male Fischer 344 Rats with Vacuolar Degeneration in the Small Intestine at 1-Year Interim Sacrifice During Dietary Exposure to Tribufos

Model | DF | X^2^ | X^2^ Goodness-of-fit p-value^a^ | Scaled residuals^b^ | | | AIC | BMD_10_ (mg/kg/day) | BMDL_10_ (mg/kg/day)
Model | DF | X^2^ | X^2^ Goodness-of-fit p-value^a^ | Dose below BMD | Dose above BMD | Overall largest | AIC | BMD_10_ (mg/kg/day) | BMDL_10_ (mg/kg/day)
Gamma^c^ | 2 | 10.39 | 0.006 | −0.63 | 2.77 | 2.77 | 38.42
Logistic | 2 | 19.73 | 0.00 | 3.80 | −0.43 | 3.80 | 49.88
Loglogistic^d^ | 2 | 2.54 | 0.28 | −0.95 | 1.03 | 1.03 | 32.52 | 0.24 | 0.08
Logprobit ^e^ | 2 | 2.67 | 0.26 | −0.90 | 1.20 | 1.20 | 32.62 | 0.25 | 0.05
Multistage (1-degree)^f^ | 2 | 10.39 | 0.006 | −0.63 | 2.77 | 2.77 | 38.42
Multistage (2-degree)^f^ | 3 | 10.39 | 0.02 | −0.63 | 2.77 | 2.77 | 36.42
Multistage (3-degree)^f^ | 3 | 10.39 | 0.02 | −0.63 | 2.77 | 2.77 | 36.42
Probit | 2 | 20.03 | 0.00 | 3.88 | −0.37 | 3.88 | 49.7
Weibull^c^ | 2 | 10.39 | 0.006 | −0.63 | 2.77 | 2.77 | 38.42
Dichotomous Hill | 2 | <0.001 | 1.00 | −0.002 | <0.001 | −0.002 | 29.22 | 1.15 | 0.16

a Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

b Scaled residuals at doses immediately below and above the BMD; also the largest residual at any dose.

c Power restricted to ≥1.

d Slope restricted to ≥1.

e Selected model. The Loglogistic, Logprobit, and dichotomous Hill models provided adequate fit to the data. BMDLs for models providing adequate fit differed by >3-fold; therefore, the model with the lowest BMDL_10_ was selected (Logprobit).

f Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMD = benchmark dose (maximum likelihood estimate of the dose associated with the selected benchmark response); BMDL_10_ = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _10_ = dose associated with 10% extra risk); DF = degree of freedom

Table A-10 Results from BMD Analysis of Incidences of Male Fischer 344 Rats with Hyperplasia in the Small Intestine Following Dietary Exposure to Tribufos for 2 Years

Model | DF | X^2^ | X^2^ Goodness-of-fit p-value^a^ | Scaled residuals^b^ | | | AIC | BMD_10_ (mg/kg/day) | BMDL_10_ (mg/kg/day)
Model | DF | X^2^ | X^2^ Goodness-of-fit p-value^a^ | Dose below BMD | Dose above BMD | Overall largest | AIC | BMD_10_ (mg/kg/day) | BMDL_10_ (mg/kg/day)
Gamma^c^ | 2 | 28.59 | 0.00 | −0.38 | 4.66 | 4.66 | 185.23
Logistic | 2 | 36.33 | 0.00 | 4.90 | −0.43 | 4.90 | 197.95
Loglogistic^d^ | 3 | 10.67 | 0.01 | 0.27 | 1.98 | −2.58
Logprobit ^e^ | 2 | 3.41 | 0.18 | −0.001 | 1.41 | 1.41 | 161.85 | 0.20 | 0.07
Multistage (1-degree)^f^ | 2 | 28.59 | 0.00 | −0.38 | 4.66 | 4.66 | 185.23
Multistage (2-degree)^f^ | 2 | 28.59 | 0.00 | −0.38 | 4.66 | 4.66 | 185.23
Multistage (3-degree)^f^ | 2 | 28.59 | 0.00 | −0.38 | 4.66 | 4.66 | 185.23
Probit | 2 | 20.03 | 0.00 | 3.88 | −0.37 | 3.88 | 49.7
Weibull^c^ | 2 | 28.59 | 0.00 | −0.38 | 4.66 | 4.66 | 185.23
Dichotomous Hill | 0 | 3.93 | NA | −0.001 | −1.12 | 1.44 | 166.44

a Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

b Scaled residuals at doses immediately below and above the BMD; also the largest residual at any dose.

c Power restricted to ≥1.

d Slope restricted to ≥1.

e Selected model. The Logprobit model was the only one to provide adequate fit to the data.

f Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMD = benchmark dose (maximum likelihood estimate of the dose associated with the selected benchmark response); BMDL_10_ = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _10_ = dose associated with 10% extra risk); DF = degree of freedom; NA = not applicable (degrees of freedom = 0, saturated model, goodness of fit p-value could not be calculated)

Table A-11 Results from BMD Analysis of Incidences of Female Fischer 344 Rats with Vacuolar Degeneration in the Small Intestine at 1-Year Interim Sacrifice During Dietary Exposure to Tribufos

Model | DF | X^2^ | X^2^ Goodness-of-fit p-value^a^ | Scaled residuals^b^ | | | AIC | BMD_10_ (mg/kg/day) | BMDL_10_ (mg/kg/day)
Model | DF | X^2^ | X^2^ Goodness-of-fit p-value^a^ | Dose below BMD | Dose above BMD | Overall largest | AIC | BMD_10_ (mg/kg/day) | BMDL_10_ (mg/kg/day)
Gamma^c^ | 3 | 21.32 | 0.00 | −0.49 | 4.20 | 4.20 | 49.23
Logistic | 2 | 25.36 | 0.00 | 4.36 | −0.36 | 4.36 | 60.34
Loglogistic^d^ | 3 | 6.84 | 0.08 | 1.85 | −1.59 | 1.85 | 39.39
Logprobit | 2 | 5.54 | 0.06 | −1.15 | 1.86 | 1.86 | 40.90
Multistage (1-degree)^e^ | 3 | 21.32 | 0.00 | −0.49 | 4.20 | 4.20 | 49.23
Multistage (2-degree)^e^ | 3 | 21.32 | 0.00 | −0.49 | 4.20 | 4.20 | 49.23
Multistage (3-degree)^e^ | 3 | 21.32 | 0.00 | −0.49 | 4.20 | 4.20 | 49.23
Probit | 2 | 20.03 | 0.00 | 3.88 | −0.37 | 3.88 | 49.7
Weibull^c^ | 3 | 21.32 | 0.00 | −0.49 | 4.20 | 4.20 | 49.23
Dichotomous Hill ^f^ | 2 | 0.002 | 1.00 | −0.025 | 0.03 | 0.03 | 34.03 | 0.71 | 0.18

a Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

b Scaled residuals at doses immediately below and above the BMD; also the largest residual at any dose.

c Power restricted to ≥1.

d Slope restricted to ≥1.

e Betas restricted to ≥0.

f Selected model. The dichotomous Hill model was the only model to provide adequate fit to the data.

AIC = Akaike Information Criterion; BMD = benchmark dose (maximum likelihood estimate of the dose associated with the selected benchmark response); BMDL_10_ = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _10_ = dose associated with 10% extra risk); DF = degree of freedom

Table A-12 Results from BMD Analysis of Incidences of Female Fischer 344 Rats with Vacuolar Degeneration in the Small Intestine Following Dietary Exposure to Tribufos for 2 Years

Model | DF | X^2^ | X^2^ Goodness-of-fit p-value^a^ | Scaled residuals^b^ | | | AIC | BMD_10_ (mg/kg/day) | BMDL_10_ (mg/kg/day)
Model | DF | X^2^ | X^2^ Goodness-of-fit p-value^a^ | Dose below BMD | Dose above BMD | Overall largest | AIC | BMD_10_ (mg/kg/day) | BMDL_10_ (mg/kg/day)
Gamma^c^ | 3 | 21.42 | 0.00 | −0.89 | 4.11 | 4.11 | 147.70
Logistic | 2 | 35.44 | 0.00 | 4.83 | −0.40 | 4.83 | 171.52
Loglogistic^d^ | 3 | 6.13 | 0.11 | −1.28 | 1.70 | 1.70 | 136.91 | 0.68 | 0.47
Logprobit ^e^ | 2 | 3.99 | 0.14 | −1.24 | 1.38 | 1.38 | 136.86 | 0.60 | 0.29
Multistage (1-degree)^f^ | 2 | 21.42 | 0.00 | −0.89 | 4.11 | 4.11 | 147.70
Multistage (2-degree)^f^ | 3 | 21.42 | 0.00 | −0.89 | 4.11 | 4.11 | 147.70
Multistage (3-degree)^f^ | 3 | 21.42 | 0.00 | −0.89 | 4.11 | 4.11 | 147.70
Probit | 2 | 35.08 | 0.00 | 4.86 | −0.44 | 4.86 | 170.57
Weibull^c^ | 2 | 21.42 | 0.00 | −0.89 | 4.11 | 4.11 | 149.70
Dichotomous Hill | 0 | <0.01 | NA | −0.02 | <0.01 | −0.02 | 135.49

a Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

b Scaled residuals at doses immediately below and above the BMD; also the largest residual at any dose.

c Power restricted to ≥1.

d Slope restricted to ≥1.

e Selected model. The loglogistic and logprobit models provided adequate fit to the data. BMDLs for models providing adequate fit were sufficiently close; therefore, the model with the lowest AIC was selected (logprobit).

f Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMD = benchmark dose (maximum likelihood estimate of the dose associated with the selected benchmark response); BMDL_10_ = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _10_ = dose associated with 10% extra risk); DF = degree of freedom; NA = not applicable (degrees of freedom = 0, saturated model, goodness of fit p-value could not be calculated)

Table A-13 Results from BMD Analysis of Incidences of Female Fischer 344 Rats with Hyperplasia in the Small Intestine Following Dietary Exposure to Tribufos for 2 Years

Model | DF | X^2^ | X^2^ Goodness-of-fit p-value^a^ | Scaled residuals^b^ | | | AIC | BMD_10_ (mg/kg/day) | BMDL_10_ (mg/kg/day)
Model | DF | X^2^ | X^2^ Goodness-of-fit p-value^a^ | Dose below BMD | Dose above BMD | Overall largest | AIC | BMD_10_ (mg/kg/day) | BMDL_10_ (mg/kg/day)
Gamma^c^ | 2 | 6.54 | 0.04 | −1.14 | 2.14 | 2.14 | 140.82
Logistic | 2 | 15.49 | <0.01 | 3.16 | −0.19 | 3.16 | 150.78
Loglogistic ^d^ ^,^ ^e^ | 2 | 3.01 | 0.22 | −1.18 | 1.02 | −1.18 | 138.03 | 1.37 | 0.93
Logprobit | 1 | 2.02 | 0.16 | −1.05 | 0.66 | −1.05 | 138.81 | 1.23 | 0.60
Multistage (1-degree)^f^ | 2 | 6.54 | 0.04 | −1.14 | 2.14 | 2.14 | 140.82
Multistage (2-degree)^f^ | 2 | 6.54 | 0.04 | −1.14 | 2.14 | 2.14 | 140.82
Multistage (3-degree)^f^ | 2 | 6.54 | 0.04 | −1.14 | 2.14 | 2.14 | 140.82
Probit | 2 | 14.97 | <0.01 | 3.14 | −0.24 | 3.14 | 150.09
Weibull^c^ | 2 | 6.54 | 0.04 | −1.14 | 2.14 | 2.14 | 140.82
Dichotomous Hill | 0 | 1.01 | NA | −0.71 | −0.00 | 0.71 | 139.19

a Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

b Scaled residuals at doses immediately below and above the BMD; also the largest residual at any dose.

c Power restricted to ≥1.

d Slope restricted to ≥1.

e Selected model. The Loglogistic and Logprobit models provided adequate fit to the data. BMDLs for models providing adequate fit were sufficiently close; therefore, the model with the lowest AIC was selected (Loglogistic).

f Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMD = benchmark dose (maximum likelihood estimate of the dose associated with the selected benchmark response); BMDL_10_ = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _10_ = dose associated with 10% extra risk); DF = degree of freedom; NA = not applicable (degrees of freedom = 0, saturated model, goodness of fit p-value could not be calculated)

The most conservative POD for deriving a chronic-duration oral MRL for tribufos is the BMDL_10_ of 0.05 mg/kg/day for vacuolar degeneration in the small intestine of the male rats at 1-year interim sacrifice generated from the logprobit model (Table A-14). Visual inspection of the dose-response curve for the logprobit model indicated adequate fit to the mean data (Figure A-1).

Table A-14 Potential PODs for Deriving a Chronic-Duration Oral MRL for Tribufos Based on BMD Analysis of Nonneoplastic Lesions in the Small Intestine of Rats Administered Tribufos in the Diet for up to 2 Years

Effect Species (duration) | BMDL_10_ (mg/kg/day) | Reference
Vacuolar degeneration in small intestine
Rat (1-year interim sacrifice) | | CalEPA 2004; EPA 1992d
Males | 0.05^a^
Females | 0.18
Rat (2-year terminal sacrifice) | | CalEPA 2004; EPA 1992d
Males | Inadequate fit
Females | 0.29
Hyperplasia in small intestine
Rat (2-year terminal sacrifice) | | CalEPA 2004; EPA 1992d
Males | 0.07
Females | 0.93

a Selected as the POD for deriving a chronic-duration oral MRL for tribufos.

BMD =benchmark dose; BMDL_10_ = 95% lower confidence limit on the BMD using 10% change from control incidence as the benchmark response (BMR); MRL = Minimal Risk Level; NOAEL = no-observed-adverse-effect level; POD = point of departure

Figure A-1 Dose-Response Curve for Logprobit Model Data for Vacuolar Degeneration in the Small Intestine from Male Fischer 344 Rats Administered Tribufos in the Diet for 1 Year During a 2-Year Oral Study

Description of Figure A-1

Adjustment for Intermittent Exposure: Not applicable

Uncertainty Factor: The BMDL_10_ of 0.05 mg/kg/day was divided by a total uncertainty factor of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = BMDL_10_ ÷ uncertainty factors 0.05 mg / kg / day ÷ (10 × 10) = 0.0005 mg / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Histopathologic lesions in the small intestines were observed in CD-1 mice receiving tribufos from the diet for 90 weeks at estimated doses of 8.4 and 11.13 mg/kg/day for males and females, respectively (EPA 1990a).

Agency Contacts (Chemical Managers): Rae T. Benedict, Ph.D.