# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of toxaphene is located in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of toxaphene is located in Table 4-2. Toxaphene is not a single molecular substance; rather, it is a complex mixture of congeners including chlorinated bornanes, bornenes, bornadienes, camphenes, and dihydrocamphenes (de Geus et al. 1999). The congeners typically contain 6–10 chlorine atoms each (de Geus et al. 1999; Lau et al. 1996). Representative structures for the different types of toxaphene congeners are shown in Figure 4-1. Although thousands of toxaphene congeners are theoretically possible based on these structures, only a few hundred are expected to be present at significant concentrations in technical toxaphene (de Geus et al. 1999; Lamb et al. 2008; Simon and Manning 2006).

The chemical structure of specific toxaphene congeners has been described using a variety of nomenclature systems, some of which are summarized in de Geus et al. (1999). This Toxicological Profile for Toxaphene employs the nomenclature system developed by Dr. Harun Parlar to refer to specific congeners (Coelhan and Parlar 1996).

Table 4-1 Chemical Identity of Toxaphene

Characteristic | Information | Reference
Chemical name | Toxaphene | ChemIDplus Advanced 2010
Synonym(s) | Campheclor; chlorinated camphene; polychlorocamphene; chlorocamphene; octachlorocamphene; technical toxaphene | ChemIDplus Advanced 2010
Registered trade name(s) | Agricide Maggot Killer; Alltox; Camphofene Huilex; Geniphene; Hercules 3956; Hercules Toxaphene; Motox; Penphene; Phenicide; Phenatox; Strobane-T; Synthetic 3956; Toxakil | IARC 1979
Chemical formula | C_10_H_10_CI_8_ (approximately) | O’Neil et al. 2006
Chemical structure^a^ | [image] | Paris and Lewis 1973
Identification numbers:
CAS Registry | 8001-35-2 | ChemIDplus Advanced 2010; NIOSH 2005 HSDB 2010 NIOSH 2005 HSDB 2010
NIOSH RTECS | XW5250000 | ChemIDplus Advanced 2010; NIOSH 2005 HSDB 2010 NIOSH 2005 HSDB 2010
EPA Hazardous Waste | P123 | ChemIDplus Advanced 2010; NIOSH 2005 HSDB 2010 NIOSH 2005 HSDB 2010
DOT/UN/NA/IMCO | NA 2761/toxaphene | ChemIDplus Advanced 2010; NIOSH 2005 HSDB 2010 NIOSH 2005 HSDB 2010
HSDB | 1616 | ChemIDplus Advanced 2010; NIOSH 2005 HSDB 2010 NIOSH 2005 HSDB 2010

a Structure representative of the predominant chlorinated camphene compounds present in technical toxaphene.

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; IARC = International Agency for Research on Cancer; NIOSH = National Institute for Occupational Safety and Health; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Toxaphene^a^

Property | Information | Reference
Molecular weight | 431.8 (approximately) | BCPC 2003
Color/form | Yellow, waxy, amber | NIOSH 2005; O’Neil et al. 2006
Physical state | Solid | O’Neil et al. 2006
Melting point | 65–90°C | O’Neil et al. 2006
Boiling point | Not applicable (dechlorinates at 155°C) | O’Neil et al. 2006
Density at 25°C | 1.65 g/cm^3^ | BCPC 2003
Odor | Mild, piney, chlorine- and camphor-like odor | NIOSH 2005
Odor threshold:
Air | 0.14 ppm (detection) | Sigworth 1965; Ruth 1986
Water | 2.4 mg/m^3^ | HSDB 2010
| 0.14 ppm (detection)
Solubility: | | Murphy et al. 1987
Water | 0.55 mg/L
Organic solvent(s) | Freely soluble in aromatic hydrocarbons; Readily soluble in organic solvents, including petroleum oils | BCPC 2003; O’Neil et al. 2006
Partition coefficients:
Log K_ow_ | 3.3–6.64 | EPA 1981; Fisk et al. 1999
Log K_oc_ | 3–5 | EPA 1981; Soubaneh et al. 2008; Wauchope et al. 1992
Vapor pressure | 6.69x10^−6^ mm Hg at 20°C | Murphy et al. 1987
Henry’s law constant | 6x10^−6^ atm-m^3^/mol at 20°C | Murphy et al. 1987
Autoignition temperature | No data
Flashpoint | 135°C (closed cup, 60% solution); 115°C (tag closed cup, 90% solution) | HSDB 2010
Flammability limits in air | Solid is not flammable, but is usually dissolved in combustible liquid | HSDB 2010
Conversion factors (25°C) | 1 ppm x 17.95(average)=1 mg/m^3^; 1 mg/m^3^ x 0.056 (average)=1 ppm | Calculated
Explosive limits | No data

a Technical toxaphene is a complex mixture of hundreds of polychlorinated bicyclic terpenes consisting predominantly of chlorinated camphenes (Jansson and Wideqvist 1983; Paris and Lewis 1973). Toxaphene contains 67–69% chlorine by weight (de Geus et al. 1983).

Figure 4-1 Representative Carbon Skeleton Structures of the Toxaphene Congeners with Numbered Carbon Atoms^a^ a Congeners typically contain 6–10 chlorine atoms.

Source: de Geus et al. 1999