# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-57, Atlanta, Georgia 30333.

## Toxaphene Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Toxaphene
CAS Number: | 8001-35-2
Date: | May 2014
Profile Status: | Final Post-Public Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 26
Species: | Dog

[underlined: Minimal Risk Level]: 0.05 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Chu I, Villeneuve DC, Sun CW, . 1986. Toxicity of toxaphene in the rat and beagle dog. Fundam Appl Toxicol 7:406–418 3781130 .

[underlined: Experimental design]: (human study details or strain, number of animals per exposure/control group, sex, dose administration details): Groups of male and female beagle dogs (6/sex/group) were given gelatin capsules containing toxaphene at 0, 0.2, 2.0, or 5.0 mg/kg daily for 13 weeks. During the first 2 treatment days, the high-dose group received toxaphene at 10 mg/kg/day. This dose was reduced to 5 mg/kg/day on treatment day 3 because the 10 mg/kg/day dose level elicited convulsions, salivation, and vomiting in 1/6 males and 2/6 females. These clinical signs were not observed in any of the toxaphene-treated dogs throughout the remainder of the scheduled 13-week treatment period.

[underlined: Effect noted in study and corresponding doses]: Serious neurological effects (convulsions, salivation, and vomiting in 1/6 males and 2/6 females) were elicited during the first 2 days of oral treatment at 10 mg/kg/ day. These effects were not elicited after the highest dose was reduced to 5 mg/kg/day on treatment day 3 and maintained at that level throughout the remainder of the scheduled 13-week treatment period.

[underlined: Dose and end point used for MRL derivation]: NOAEL of 5 mg/kg/day for neurological effects; the LOAEL was 10 mg/kg/day for clinical signs (convulsions, salivation, and vomiting in 1/6 males and 2/6 females). Support for a NOAEL of 5 mg/kg/day for neurological effects is provided by the results of another dog study in which a single 5 mg/kg dose of toxaphene elicited no clinical signs of neurotoxicity, whereas a single 10 mg/kg dose resulted in convulsions (Lackey 1949). Although both studies identified a serious LOAEL of 10 mg/kg/day for neurological effects, the NOAEL of 5 mg/kg/day (identified in both studies) is considered adequate basis for deriving an acute-duration oral MRL for toxaphene.

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? No.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Lackey (1949) reported convulsions in 4/5 fasted dogs administered toxaphene (in corn oil) once by capsule at 10 mg/kg. Higher single dose levels (15–50 mg/kg) resulted in convulsions and mortalities; there were no signs of convulsions in three dogs dosed at 5 mg/kg. Seriously depressed maternal weight gain in pregnant rats and mice have been observed at toxaphene doses in the range of 15–32 mg/kg/day (Chernoff and Carver 1976; Chernoff et al. 1990). The dose necessary to induce nonfatal convulsions in humans has been estimated to be approximately 10 mg/kg (CDC 1963).

[underlined: Agency Contacts (Chemical Managers)]: Nickolette Roney, MPH

## Toxaphene Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Toxaphene
CAS Number: | 8001-35-2
Date: | May 2014
Profile Status: | Final Draft Post-Public Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 47
Species: | Monkey

[underlined: Minimal Risk Level]: 0.002 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Tryphonas H, Arnold DL, Bryce F, . 2001. Effects of toxaphene on the immune system of cynomolgus (Macaca fascicularis) monkeys. Food Chem Toxicol 39:947–958 11498272 .

[underlined: Experimental design]: (human study details or strain, number of animals per exposure/control group, sex, dose administration details): Groups of 10 female cynomolgus monkeys/dose group (approximately 7 years of age on average) were administered toxaphene by oral capsules at 0, 0.1, 0.4, or 0.8 mg/kg/day for up to 75 weeks. Groups of five males were similarly dosed at 0 or 0.8 mg/kg/day (approximately 12.5 and 6 years of age on average, respectively). Testing for immune effects was initiated on week 33 and included flow cytometry, lymphocyte transformation, natural killer cell activity, and determination of serum cortisol during weeks 33–46 and immunizations with SRBC at treatment week 44 a primary response and week 48 for a secondary response (observations made through treatment week 52).

[underlined: Effect noted in study and corresponding doses]: Treatment with toxaphene at 0.4 mg/kg/day resulted in significant (p<0.05) reductions in mean primary anti-SRBC IgM responses at weeks 1 and 4 following primary immunization (27 and 35% lower than that of controls) and secondary anti-SRBC IgM responses at week 1 following secondary immunization (10% lower than that of controls). The dose level of 0.8 mg/kg/day resulted in significantly reduced mean primary anti-SRBC IgM responses at weeks 1–4 following primary immunization, significantly reduced mean secondary anti SRBC IgM response at weeks 1 and 4 following secondary immunization, and significantly reduced primary anti-SRBC IgG responses at weeks 2 and 3 following primary immunization (51 and 43% lower than that of controls). In males, 0.8 mg/kg/day toxaphene induced a significant reduction in mean primary anti-SRBC IgM response at weeks 1–3 following primary immunization. Flow cytometry tests showed that the only effect on leukocyte and lymphocyte subsets was a reduction in absolute B lymphocytes (CD20) in 0.8 mg/kg/day females (62% lower than controls). There were no detectable treatment-related effects on natural killer cell activity, lymphoproliferative response to mitogens, or serum cortisol levels. Table A-1 shows the results of primary anti-SRBC IgM responses.

Table A-1 Mean Anti-SRBC (IgM) Titres at 1–4 Weeks Post-Immunization in Female Cynomolgus Monkeys Administered Toxaphene in Gelatin Capsule Daily for 75 Weeks Including 44 Weeks Prior to Immunization

Toxaphene dose (mg/kg/day) | Weeks post-immunization (mean log_2_ titres ± standard error)^a^
Toxaphene dose (mg/kg/day) | 1 | 2 | 3 | 4
0 | 7.10±0.35 | 6.40±0.31 | 5.30±0.34 | 4.90±0.41
0.1 | 6.40±0.54 | 5.20±0.73 | 450±0.64 | 4.00±0.61
0.4 | 5.20±0.79^b^ | 460±0.78 | 3.80±0.85 | 3.20±0.63^b^
0.8 | 3.70±0.83^b^ | 3.00±0.88^b^ | 3.00±0.75^b^ | 2.80±0.61^b^

a Mean values calculated from 10 animals per treatment group.

b p<0.05.

Source: Tryphonas et al. 2001

All continuous variable models in the EPA Benchmark Dose Software (Version 2.1.1) were fit to the mean anti-SRBC (IgM) titre data at week 1 post-immunization; standard error values were converted to standard deviation values prior to running the models. A default benchmark response (BMR) of 1 standard deviation (1 SD) from the control mean was selected in the absence of a toxicological rationale for selecting an alternative BMR. Model results for the mean anti-SRBC (IgM) titre data are shown in Table A-2. The linear model was initially fit to the data using constant variance, but failed to meet conventional goodness-of-fit criteria for modeled variance (p=0.04395). Adequate fit for modeled variance was obtained, however, when fit to the data using non-constant variance. Therefore, nonconstant variance was selected to fit the remaining continuous variable models to the data. The Hill model failed the test for mean fit (degrees of freedom <0) and was not considered further. Using nonhomogeneous variance, the polynomial (2- and 3-degree), and power models converged on the linear model and provided identical predictions of the BMD_1SD_ (0.34 mg/kg/day) and the 95% lower confidence limit on the BMD_1SD_ (BMDL_1SD_; 0.22 mg/kg/day). The fit of the linear model to the malformation data is presented in Figure A-1. This figure is identical to those generated from the polynomial (2- and 3-degree), and power models.

Table A-2 Model Predictions for Mean Anti-SRBC (IgM) Titre Data at Week 1 Post-Immunization from Female Cynomolgus Monkeys Administered Toxaphene in Gelatin Capsule Daily for 75 Weeks Including 44 Weeks Prior to Immunization

Model | Variance p-value^a^ | Means p-value^a^ | Scaled residual of interest^b^ | AIC | BMD_1SD_ (mg/kg/day) | BMDL_1SD_ (mg/kg/day)
Constant variance
Linear^c^ | 0.04395 | 0.9335 | −0.15 | 100.43 | – | –
Nonconstant variance
Linear^c^ | 0.48 | 0.41 | −0.16 | 97.45 | 0.34 | 0.22
Polynomial (2-degree)^c^ | 0.48 | 0.41 | −0.16 | 97.45 | 0.34 | 0.22
Polynomial (3-degree)^c^ | 0.48 | 0.41 | −0.16 | 97.45 | 0.34 | 0.22
Power^d^ | 0.48 | 0.41 | −0.16 | 97.45 | 0.34 | 0.22
Hill^c^ | 0.48 | NA^e^ | 0.26 | 99.68 | 0.14 | 0.04

a Values <0.10 fail to meet conventional goodness-of-fit criteria.

b Scaled residual at measured response closest to the benchmark response.

c Coefficients restricted to be negative.

d Power restricted to ≥1.

e Degrees of freedom for test of mean fit are less than or equal to 0; the χ^2^ test for fit is not valid.

AIC = Akaike’s Information Criterion; BMD = maximum likelihood estimate of the dose/concentration associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD; SD = standard deviation

Figure A-1 Predicted and Observed Mean Anti-SRBC (IgM) Titres from Female Cynomolgus Monkeys Administered Toxaphene in Gelatin Capsule Daily for 75 Weeks Including 44 Weeks Prior to Immunization^*^ * BMD and BMDL associated with 1 standard deviation from the estimated control mean are shown; doses given in units of mg/kg/day.

The linear model form and parameters output from benchmark dose analysis of anti-SRBC titres from female cynomolgus monkeys of the principal study (Tryphonas et al. 2001) follows:

   The form of the response function is:                Y[dose] = beta_0 + beta_1*dose +
beta_2*dose^2 + ...

Dependent variable = mean
Independent variable = dose
The polynomial coefficients are restricted to be negative
The variance is to be modeled as Var(i) = exp(lalpha + log(mean(i)) * rho)

Total number of dose groups = 4
Total number of records with missing values = 0
Maximum number of iterations = 250
Relative Function Convergence has been set to: 1e-008
Parameter Convergence has been set to: 1e-008

                Default Initial Parameter Values
                       lalpha =      1.46271
                       rho =            0
                       beta_0 =       6.94194
                       beta_1 =      -4.12903


         Asymptotic Correlation Matrix of Parameter Estimates

                  lalpha             rho         beta_0        beta_1

lalpha                1         -0.99           -0.077            0.2

rho                  -0.99       1                0.076          -0.2

beta_0               -0.077      0.076            1              -0.6

beta_1                0.2       -0.2            -0.6              1


         Parameter Estimates     95.0% Wald Confidence Interval

Variable             Estimate              Std. Err.      Lower Conf. Limit    Upper Conf. Limit
lalpha               4.87328                1.76864              1.40682              8.33975
rho                 -2.14694                1.03446             -4.17445             -0.119432
beta_0               6.95256                0.342736             6.28081              7.62431
beta_1              -4.14011                1.02288             -6.14492             -2.13531


         Table of Data and Estimated Values of Interest

Dose        N      Obs Mean      Est Mean       Obs Std Dev    Est Std Dev    Scaled Res.

 0         10          7.1            6.95             1.11           1.43         0.327
 0.1       10          6.4            6.54             1.71           1.52        -0.288
 0.4       10          5.2            5.3              2.5            1.91        -0.16
 0.8       10          3.7            3.64             2.62           2.86         0.0659


Model Descriptions for likelihoods calculated


Model A1: Yij = Mu(i) + e(ij) Var{e(ij)} = Sigma^2

Model A2: Yij = Mu(i) + e(ij) Var{e(ij)} = Sigma(i)^2

 Model A3: Yij = Mu(i) + e(ij) Var{e(ij)} = exp(lalpha + rho*ln(Mu(i)))
Model A3 uses any fixed variance parameters that were specified by the user

Model    R: Yi = Mu + e(i) Var{e(i)} = Sigma^2


                  Likelihoods of Interest

         Model        Log(likelihood)        # Param's        AIC

         A1            -47.147015                 5       104.294030

         A2            -43.095974                 8       102.191948

         A3            -43.837856                 6        99.675711

         fitted        -44.727388                 4        97.454776

         R             -54.279147                 2       112.558295



                  Explanation of Tests

Test 1:    Do responses and/or variances differ among Dose levels? (A2 vs. R)

Test 2:    Are Variances Homogeneous? (A1 vs A2)

Test 3:    Are variances adequately modeled? (A2 vs. A3)

Test 4:    Does the Model for the Mean Fit? (A3 vs. fitted)


(Note:    When rho=0 the results of Test 3 and Test 2 will be the same.)



                  Tests of Interest

Test        -2*log(Likelihood Ratio)         Test df             p-value

Test   1                   22.3663             6                0.001039
Test   2                    8.10208            3                0.04395
Test   3                    1.48376            2                0.4762
Test   4                    1.77906            2                0.4108

The p-value for Test 1 is less than .05. There appears to be a difference between
response and/or variances among the dose levels. It seems appropriate to model the
data

The p-value for Test 2 is less than .1.                A non-homogeneous variance model appears to
be appropriate

The p-value for Test 3 is greater than .1.                The modeled variance appears to be
appropriate here

The p-value for Test 4 is greater than .1.                The model chosen seems to adequately
describe the data


                  Benchmark Dose Computation

Specified effect =               1

Risk Type	 =       Estimated standard deviations from the control mean

Confidence level =             0.95

             BMD =            0.3445

            BMDL =          0.219859

[underlined: Dose and end point used for MRL derivation]: A BMDL_1SD_ of 0.22 mg/kg/day for decreased anti-SRBC(IgM) titers as an indicator of decreased humoral immunity.

[ ] NOAEL [ ] LOAEL [X] BMD

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? No.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: In an enzyme-linked immunosorbent assay (ELISA) performed on female mice that received toxaphene from the diet at doses ≥19 mg/kg/day for up to 8 weeks, Allen et al. (1983) reported suppressed antibody production, indicating depressed humoral immunity; the study identified a NOAEL of 2 mg/kg/day for the effect. Koller et al. (1983) reported a 46% decrease in the IgG primary antibody response in male rats receiving toxaphene from the diet at 2.6 mg/kg/day for up to 9 weeks and challenged twice (after 8 and 15 days on test) with keyhole limpet hemocyanin (KLH).

[underlined: Agency Contacts (Chemical Managers)]: Nickolette Roney, MPH