# 8 REFERENCES

3M. 1993. Organic vapor monitor analysis guide for organic vapor monitors 3500/3510 and organic vapor monitors 3520/3530. 3M Company, Occupational Health and Sefety Division, St. Paul. 70-0702-1914-5(113.5)R.
ABB-Environmental. 1990. Compilation of data on the composition, physical characteristics and water solubility of fuel products. Prepared for Massachusetts Department of Environmental Protection. Wakefield, Massachusetts.
ACGIH. 1994. American conference of governmental industrial hygienists 1993-1994. Threshold Limit Values for Chemical Substances and Physical Agents and Biological Exposure Indices, 22.
ACGIH. 1997. Threshold limit values for chemical substances and physical agents and biological exposure indices. ACGIH, Cincinnati, OH., 44–46.
Air Force. 1989. Gasoline. In: The installation restoration program toxicology guide. Volume 4. Contract no. DE-AC05840R21400. Wright-Patterson Air Force Base, OH. Document no. 65-1-65-46.
Air Force. 1991. Tumorigenic evaluation of jet fuels JP-TS and JP-7. Report No, AAMRL-TR-91-0020. Wright-Patterson Air Force Base, OH. Aerospace Medical Research Laboratory, Aerospace Medical Division, U.S. Air Force Systems Command.
Akamaguna AI, Odita JC. 1983. Radiology of kerosene poisoning in young children. Ann Trop Paediatr 3(2):85–88.6197013
Albro PW, Fishbein RO. 1970. Absorption of aliphatic hydrocarbons by rats. Biochem Biophys Acta 219:437–446.5497201
Aldy D, Siregar R, Siregar H. 1978. Accidental poisoning in children with special reference to kerosene poisoning. Paediatr Indones 18(1-2):45–50.652367
Amherst. 1999. Annual conferences. American Association for the Environmental Health of Soils. http://www.aehs.com. Amherst, Massachusettes.
Andrew FD, Buschborn RL, Cannon WC, 1981. Teratologic assessment of ethylbenzene and 2-ethoxyethanol. Richland, WA: Battelle Pacific Northwest Laboratory. PB83-208074, 108.
Annobil SH. 1983. Chest radiographic patterns following kerosene poisoning in Ghanaian children. Clin Radio 134(6):643–646.
Annobil SH, Ogunbiyi OA. 1991. Pulmonary radiology changes in kerosene poisoning in the Asir region of Saudia Arabia. Ann Trop Paediatr 11(4):391–395.1721801
Anziulewicz JA, Dick HJ, Chiarulli EE. 1959. Transplacental naphthalene poisoning. Am J Obstet Gynecol78:519-521.
APHA. 1992. Standard methods for the examination of water and wastewater. Prepared and published jointly by American Public Health Association, American Water Works Association, and Water Environment Federation. Washington, DC.
API. 1993. Petroleum product surveys. American Petroleum Institute, Washington, DC.
API. 1995a. Index and abstracts of API health-related Research. 13th Edition. 1959-1994. Health and Environmental Sciences Department, American Petroleum Institute. Washington, DC.
API. 1995b. Protecting our planet: Strategies for today’s environmental partnership. Washington, DC: American Petroleum Institute (available at http://www.api.org/step/).
API. 1996. Petroleum facts at a glance. January-December 1995. American Petroleum Institute. http:llwww.api.orglnews/faqsl
API. 1998a. Monthly petroleum facts at a glance. January-December 1997. American Petroleum Institute. http://www.api.org/faqs/
API. 1998b. Petroleum industry environmental performance, 6’h annual report. American Petroleum Institute, Washington, DC.
Ashley DL, Bonin MA, Cardinali FL, 1992. Determining volatile organic compounds in human blood from a large sample population by using purge and trap gas chromatography/mass spectrometry. Anal Chem 64(9):1021–1029.1590585
ASTM. 1992. Manual on hydrocarbon analysis, 5th. American Society for Testing and Materials. West Conshohocken, PA.
ASTM. 1994. Annual book of ASTM standards; section 11, water and environmental technology. Standard test methods for analysis of selected elements in waterborne oils. American Society for Testing and Materials. Philadelphia, PA.
ASTM. 1995. E 1739-95: Standard guide for risk-based corrective action applied at petroleum release sites. Published November 1995. Editorial changes made throughout in December 1996. American Society for Testing and Materials. West Conshohocken, PA.
Atlas RM, Cerniglia CE. 1995. Bioremediation of petroleum pollutants. Bioscience 45(5):332–338.
ATSDR. 1992. Public health assessment guidance manual. Agency for Toxic Substances and Disease Registry, Atlanta, GA.
ATSDR. 1994. Toxicological profile for toluene (update). Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA. TP-93/14.
ATSDR. 1995a. Toxicological profile for automotive gasoline. Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA. NTIS PB95-264206.
ATSDR. 1995b. Toxicological profile for Stoddard solvent. Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA. NTIS PB95-264263.
ATSDR. 1995c. Toxicological profile for jet fuels (JP-4 and JP-7). Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA. NTIS PB95-264230.
ATSDR. 1995d. Toxicological profile for xylenes (update). Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA.
ATSDR. 1995e. Toxicological profile for naphthalene (update). Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA.
ATSDR. 1995f. Toxicological profile for polycyclic aromatic hydrocarbons (PAHs) (update). Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA.
ATSDR. 1995g. Toxicological profile for fuel oils. Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA. NTIS PB95-264222.
ATSDR. 1996a. Toxicological profile for methyl-tert-butyl ether. Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA.
ATSDR. 1996b. Minimal risk levels for priority substances and guidance for derivation, republication. Federal Register. 61 FR 125:335 11-33520.
ATSDR. 1997a. Toxicological profile for benzene (update). Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA.
ATSDR. 1997b. Toxicological profile for hydraulic fluids. Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA.
ATSDR. 1997c. Toxicological profile for mineral-based crankcase oil. Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA.
ATSDR. 1998a. Hazardous Substance Release/Health Effects Database. Internet. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/hazdat.html.
ATSDR. 1998b. Toxicological profile for jet fuels (JP-5 and JP-8). Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA.
ATSDR. 1998c. Toxicological profile for mineral-based crankcase oil. Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA.
ATSDR. 1999a. Toxicological profile for ethylbenzene. Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA.
ATSDR. 1999b. Toxicological profile for hexane. Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA.
Baelum J, Andersen I, Lundqvist GR, 1985. Response of solvent-exposed printers and unexposed controls to six-hour toluene exposure. Stand J Work Environ Health 11:271–280.
Barnes D, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Bauman BJ. 1988. Soils contaminated by motor fuels: Research activities and perspectives of the American Petroleum Institute. In: Petroleum contaminated soils, vol. 1. Chelsea, MI: Lewis Publishers, 3–19.
BC. 1995. Recommendations to British Columbia environment for development of remediation criteria or petroleum hydrocarbons in soil and groundwater, Vol 1. Industrial Wastes and Hazardous Contaminants Branch, Ministry of Environment, Lands and Parks. Victoria, B.C.
Belisle AA, Gay ML, Coon NC. 1981. Comparison of 2 extraction methods for the analysis of petroleum hydrocarbon residues in mallard duck eggs by gas chromatography and gas chromatography-mass spectrometry. Chemosphere 10(11-12): 1197–1204.
BLM. 1982. Requirements for operating rights owners and operators. Bureau of Land Management, Interior. Code of Federal Regulations. 43 CFR 3 162.
BNA. 1999. State environment and safety regulatory monitoring report, CD Rom. Bureau of National Affairs, Washington, DC.
Bonazountas M. 1988. Mathematical pollutant fate modeling of petroleum products in soil systems. In: Calabrese EJ, Kostecki, eds. Soils contaminated by petroleum: Environmental and public health effects. New York, NY: John Wiley and Sons, 31–97.
Bonazountas M. 1991. Fate of hydrocarbons in soils: review of modeling practices. In: Kostecki PT, Calabrese EJ, Bell CE, eds. Hydrocarbon contaminated soils and groundwater; Vol. I: Analysis, fate, environmental and public health effect remediation. Chelsea, MI: Lewis Publishers, 167–185.
Borden RC, Bedient PB, Lee MD, 1986. Transport of dissolved hydrocarbons influenced by oxygen-limited biodegradation: 2. Field application. Water Resources Research Vol 22(13):1983–1990.
Bossert ID, Bartha R. 1986. Structure-biodegradability relationships of polycyclic aromatic hydrocarbons in soil. Bull Environ Contam Toxicol, 37(4):490–495.3768542
BP. 1996. Summary tables of laboratory analysis for diesel and fuel oil #2, personal communication from B. Albertson, Friedman and Bruya, Inc., Seattle, WA, developed for British Petroleum.
Bruner RH, Kinkead ER, O’Neill TP, 1993. The toxicologic and oncogenic potential of JP-4 jet fuel vapors in rats and mice: 12-month intermittent inhalation exposures. Fund Appl Toxicol 20:97–110.
Burris DR, MacIntyre WG. 1984. Water solubility behavior of hydrocarbon mixtures -- Implications for petroleum dissolution. In: Vandermeulen JH, Hiudey SE, eds. Oil in freshwater: Chemistry, biology, countermeasure technology. New York,NY: Pergamon Press, 85–94.
Bus JS, White EL, Tyl RW, 1979. Perinatal toxicity and metabolism of n-hexane in Fischer-344 rats after inhalation exposure during gestation. Toxicol Appl Pharmacol 51(2):295–302.531893
Bushy Run. 1989a. Developmental toxicity study of commercial hexane vapor in CD (Sprague-Dawley) Rats. Unpublished study by Bushy Run Research Center, Export PA. Prepared for the American Petroleum Institute Washington DC. EPA TSCA Section 4 submission OTS0524323.
Bushy Run. 1989b. Developmental toxicity study of commercial hexane vapor in CD-l mice. Unpublished study by Bushy Run Research Center, Export PA. Prepared for the American Petroleum Institute, Washington DC. EPA TSCA Section 4 submission OTS0524323.
Calabrese E. 1978. Pollutants and high risk groups: The biological basis of increased human susceptibility to environmental and occupational pollutants. New York, NY: John Wiley and Sons.
Castilla-Serna L, Rodriguez-Perez, Osorio-Cruces F, 1991. Effects of chronic toluene inhalation on avoidance conditioned behavior in rats. Arch Invest Med 22:295–301.
Cavender F. 1994. Aliphatic hydrocarbons. In: Clayton GD, Clayton FE, eds. Patty’s industrial hygiene and toxicology. Fourth Edition, Vol. II, Part B. New York: John Wiley & Sons, 1221–1266.
Chang DY, Lopez I, Yocklovich SG. 1992. Determination of kerosene and #2 diesel in soil by purge and trap vs. extraction procedure. Journal of Soil Contamination 1(3):239–251.
Charbeneau RJ, Weaver JW. 1992. Modeling contaminant transport through subsurface systems. 4’h Annual Symposium “Groundwater: the problem and some solutions” proceedings, April 2-3, 1992. pp 179–198.
Charbeneau R, Weaver JW, Lien BK. 1995. Hydrocarbon spill screening model (HSSM). Vol. 2. Theoretical background and source codes. U.S. Environmental Protection Agency. Robert Kerr Environmental Research Lab, Ada, OK.
Clark DB, Butterworth ST, Martin JG, 1989. Inhalation toxicity of high flash aromatic naphtha. Toxic Ind Health 5(3):415–428.
Clark RM, Vicory AH, Goodrich JA. 1990. The Ohio River oil spill: A case study. Journal of the American Water Works Association (March 1990):39–44.
Coate WB, Hoberman AM, Durloo RS. 1984. Inhalation teratology study of benzene in rats. Adv Mod Environ Toxicol 6:187–198.
Coleman E, Munch JW, Streicher RP, 1984. The identification and measurement of components in gasoline, kerosene, and No. 2 fuel oil that partitions into the aqueous phase after mixing. Arch Env Cont Tox 13:171–178.
CONCAWE. 1986. Method for monitoring exposure to gasoline vapour in air. The Hague, Netherlands. PB90-269713.
Condie LW, Hill JR, Borzelleca JF. 1988. Oral toxicology studies with xylene isomers and mixed xylenes. Drug Chem Toxicol 11:329–354.3243184
Cox BA, Anderson JW, Parker JC. 1975. An experimental oil spill: The distribution of aromatic hydrocarbons in the water, sediment, and animal tissues within a shrimp pond. In: Proceedings of the Conference on the Prevention and Control of Oil Pollution, 607–612.
Cushman JR, Norris JC, Dodd DE, 1995. Subchronic inhalation toxicity and neurotoxicity assessment of cumene in Fischer 344 rats. J Am Co11 Toxicol 14(2): 129–147.
Daugherty SJ. 1991. Regulatory approaches to hydrocarbon contamination and underground storage tanks. In: Hydrocarbon contaminated soils and groundwater: analysis, fate, environmental and public health effects, and remediation. Vol. 1. Chelsea MI: Lewis Publishers, Inc., 23–53.
Daugherty SJ. 1993. Hydrocarbon contamination in the subsurface: Realities, issues, and prospects. In: Kostecki P, Calabrese E, eds. Hydrocarbon contaminated soils and groundwater, vol 3. Chelsea MI: Lewis Publishers, Inc., 3–18.
Daughtrey WC, Duffy JS, Haddock LS, 1994. Chronic inhalation study of commercial hexane in mice. Toxicologist 14:317 (Abstract #1234).
Deerhake ME, n.d. Human and ecological risk assessment for the petroleum refining waste listing determinations background document. Prepared for the Office of Solid Waste, U.S. Environmental Protection Agency, by Research Triangle Institute under Contract No. 68-W-4-0042.
Deichmann WB, Kitzmiller KV, Witherup BS, 1944. Kerosene intoxication. Ann Intern Med 21:803–823.
De Rosa CT, Johnson BL, Fay M, Hansen H, Mumtaz MM. 1996. Public health implications of hazardous waste sites: Findings, assessment and research. Food Chem Toxicol 34: 1131-l 138.9119326
De Rosa CT, Stevens Y- W, Johnson BL. 1993. Cancer policy framework for: Public health assessment of carcinogens in the environment. Toxicol Ind Health 9:559–575.8296311
DOD. 1995. Defense environmental restoration program: Annual report to congress for fiscal year 1994, March 31, 1995. Washington, DC. U.S. Department of Defense (available at http://www.dtic.dla.mil/envirodod/derpreport/toc.htmI).
DOT 1990. Hazardous materials table, special provisions, hazardous materials communications, emergency response information, and training requirements. Subpart B: Tables of Hazardous Materials and Special Provisions. Purpose and Use of Hazardous Materials Table. U.S. Department of Transportation. Code of Federal Regulations. 49 CFR 172.101.
Dowty BJ, Laseter JL, Storer J. 1976. The transplacental migration and accumulation in blood of volatile organic constituents. Pediatr Res 10:696–701.934736
Doyle Jack. 1994. Crude awakening: The oil mess in America. Washington, DC: Friends of the Earth.
Dragun J. 1988. Microbial degradation of petroleum products in soil. In: Calabrese E, Kostecki P, eds. Soils contaminated by petroleum: Environmental and public health effects. New York, NY: John Wiley and Sons, 289–298.
Dudek B, Gralewicz K, Jakubowski M, 1990. Neurobehavioral effects of experimental exposure to toluene, xylene and their mixture. Pol J Occup Med 3:109–116.2132931
Dyer RS, Bercegeay MS, Mayo LM. 1988. Acute exposures to p-xylene and toluene alter visual information processing. Neurotoxicol Teratol 10:147–153.3398823
Engineering EA. 1995. Selection of surrogate fractions based on fate and transport considerations. Total Petroleum Hydrocarbon Criteria Working Group Project #3. Prepared for U.S. Air Force, Armstrong Laboratory
Eastcott L, Shiu WY, Mackay D. 1989. Modeling petroleum products in soils. In: Petroleum contaminated soils, Vol. 1. Chelsea, MI: Lewis Publishers, Inc., 63–80.
Elovaara E, Engstrom K, Hayri L, 1989. Metabolism of antipyrine and m-xylene in rats after prolonged pretreatment with xylene alone or xylene with ethanol, phenobarbital, or 3-methylcholanthrene. Xenobiotica 19:945–960.2815836
EPA. 1971. Criteria for state, local, and regional oil removal contingency plans. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 109.
EPA. 1973a. Oil pollution prevention. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 112.
EPA. 1973b. Liability limits for small onshore storage facilities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 113.
EPA. 1974. Civil penalties for violation of oil pollution prevention regulations. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 114.
EPA. 1979a. Criteria for classification of solid waste disposal facilities and practices. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 257.
EPA. 1979b. Polychlorinated biphenyls (PCBs) manufacturing, processing, distribution in commerce, and use prohibitions. Subpart D: Storage and disposal. Disposal Requirements. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 761.60.
EPA. 1979c. Methods for chemical analysis of water and wastes: Method 418.1 (spectrophotometric, infrared); petroleum hydrocarbons, total recoverable. U.S. Environmental Protection Agency, EPA-600-79-020.
EPA. 1979d. Methods for chemical analysis of water and wastes: Method 413.2 (spectrophotometric, infrared); oil and grease, total recoverable. U.S. Environmental Protection Agency, EPA-600-79-020.
EPA. 1979e. Methods for chemical analysis of water and wastes: Method 413.1 (gravimetric, separatory funnel extraction); oil and grease, total recoverable. U.S. Environmental Protection Agency, EPA-600-79-020.
EPA. 1980a. Underground injection control program: criteria and standards. Subpart C: Criteria and standards applicable to class ii wells. U.S. Environmental Protection Agency. Code of Federal Regulations. 46 CFR 146.
EPA. 1980b. Hazardous waste management system: General. Subpart B: Definitions. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 260.10.
EPA. 1980c. Identification and listing of hazardous waste. Exclusions: Solid wastes which are not hazardous wastes. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.4. NTIS No. PB81-190019.
EPA. 1981a. Hazardous wastes from non-specific sources: Petroleum refinery primary and secondary oil/water/solids separation sludges (F037, F038). U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.31.
EPA. 1981b. Identification and listing of hazardous waste. Subpart D: Lists of hazardous wastes; hazardous wastes from specific sources: Petroleum refining wastes (K048 - K0.52). U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.32.
EPA. 1983a. Underground injection control program. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 144.
EPA. 1983b. EPA administered permit programs: The national pollutant discharge elimination system. Subpart B: Permit application and special NPDES program requirements. General Permits. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 122.28.
EPA. 1984. State underground injection control programs. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 147.
EPA. 1985a. Identification and listing of hazardous waste. Definition of solid waste. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.2.
EPA. 1985b. Identification and listing of hazardous waste. Requirements for recyclable materials. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.6.
EPA. 1985c. Designation, reportable quantities, and notification. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4.
EPA. 1986. Guidelines for the health risk assessment of chemical mixtures. Fed Reg 51:34014–34025.
EPA. 1987a. Report to Congress: Management of wastes from the exploration, development, and production of crude oil, natural gas, and geothermal energy. U.S. Environmental Protection Agency Office of Solid Waste and Emergency Response, Washington, DC. EPA/530-SW-88-003. December 1987.
EPA. 1987b. Discharge of oil. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 110.
EPA. 1987c. Evaluation of the carcinogenicity of unleaded gasoline. U.S. Environmental Protection Agency. Washington, DC. EPA/600/6-87/001.
EPA. 1987d. Criteria for the classification of solid waste disposal facilities and practices. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 257.
EPA. 1987e. Underground storage tanks; proposed rule. U.S. Environmental Protection Agency. Code of Federal Regulations, 40CFR280-281.
EPA. 1988a. Compendium of Methods for the determination of toxic organic compounds in ambient air. U.S. Environmental Protection Agency. EPA 600/4-89/017, June 1988.
EPA. 1988b. Technical standards and corrective action requirements for owners and operators of underground storage tanks (UST). U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 280.
EPA. 1988c. Treatment standards. U.S. Environmental Protection Agency. Code of Federal Regulations, 40CFR268, Subpart D. Washington, DC.
EPA. 1989a. Health and environmental effects document for n-hexane. U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response, Washington, DC.
EPA. 1989b. Health and environmental effects document for n-heptane. U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response, Washington, DC.
EPA. 1989c. Health and environmental effects document for methylcyclohexane. U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response, Washington, DC.
EPA. 1989d. Risk assessment guidance for superfund. Volume I. Human health evaluation manual (Part A). Office of Emergency and Remedial Response, Washington, DC. EPA/540/i-89/001.
EPA. 1990a. Identification and listing of hazardous waste. Subpart C: Characteristic of hazardous waste; toxicity characteristic. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.24.
EPA. 1990b. EPA administered permit programs: The national pollutant discharge elimination system. Subpart B: Permit application and special NPDES program requirements. Storm Water Discharges. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 122.26.
EPA. 1990c. Interim methods for development of inhalation reference doses. U.S. Environmental Protection Agency, Office of Research and Development. Washington, DC. EPA 600/8-90-066A.
EPA. 1991a. Standards for the management of specific hazardous wastes and specific types of hazardous waste management facilities. Subpart H: Hazardous waste burned in boilers and industrial furnaces. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 266, Subpart HH.
EPA. 1991b. Criteria for municipal solid waste landfills. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 258.
EPA. 1992a. Hazardous waste management system: Identification and Listing of hazardous waste; recycled used oil management standards. Part IX: Relationship to other programs--International Convention for Prevention of Pollution from Ships (MARPOL 73/78). U.S. Environmental Protection Agency. Final Rule. Federal Register. 57 FR 41605. September 10, 1992.
EPA. 1992b. Recycled used oil management standards. U.S. Environmental Protection Agency. Federal Register. 57 FR 41566.
EPA. 1992c. Identification and listing of hazardous waste. Definition of hazardous waste. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.3.
EPA. 1992d. Standards for the management of used oil. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 279.
EPA. 1993a. Report to congress on hydrogen sulfide air emissions Associated with the extraction of oil and natural gas. U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards, Research Triangle Park, NC. EPA-453/R-93-045.
EPA. 1993b. Fact sheet for the multi-sector stormwater general permit. Part VIII: Specific requirements for discharges associated with specific industrial activities. U.S. Environmental Protection Agency. Notice. Federal Register. 60 FR 61146. November 19, 1993.
EPA. 1993c. Provisional guidance for quantitative risk assessment of polycyclic aromatic-hydrocarbons. U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Cincinnati, OH. EPA/600/02 1.
EPA. 1994a. Cleaning up the nation’s waste sites: Markets and technology trends. EPA 542-R-92-012 (PB93-140762). Rockville, MD: Government Institutes Inc. for EPA Office of Solid Waste and Emergency Response.
EPA. 1994b. Recovered oil exclusion. U.S. Environmental Protection Agency. Federal Register. 59 FR 38542.
EPA. 1995a. Identification and listing of hazardous wastes: Petroleum refining. U.S. Environmental Protection Agency. Federal Register. 60 FR 57752
EPA. 1995b. Hazardous waste management system; identification and listing of hazardous waste: Petroleum refining process wastes; land disposal restrictions for newly identified wastes; and CERCLA hazardous substance designation and reportable quantities. U.S. Environmental Protection Agency. Notice of Proposed Rule Making. Federal Register. 60 FR 57747. November 20, 1995.
EPA. 1995c. RBCA Leaflet. U.S. Environmental Protection Agency, Office of Underground Storage Tanks. EPA 5 10-F-95-001.
EPA. 1995d. Test methods for evaluating solid waste; physical/chemical methods. U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response. SW-846.
EPA. 1996a. Guidelines establishing test procedures for the analysis of oil and grease and total petroleum hydrocarbons. Environmental Protection Agency. Proposed Rule. Federal Register. 61 FR 1730. January 23, 1996
EPA. 1996b. Risk assessment issue paper for: Derivation of a provisional oral RfD for 1,3,5-trimethylbenzene. Superfund Health Risk Technical Support Center, National Center for Environmental Assessment, Cincinnati, OH. (96-012/03-08-96)
EPA. 1997a. Health effects assessment summary tables FY 1997 update. Office of Research and Development, Office of Emergency and Remedial Response, Washington, DC. NTIS PB97-921199.
EPA. 1997b. Toxicological review of cumene (CAS No. 98-82-8). In Support of Summary Information on the Integrated Risk Information System. June 1997. U.S. Environmental Protection Agency, Washington, DC.
EPA. 1998a. Fact sheet: Proposed test procedure for the analysis of oil and grease and total petroleum hydrocarbons. http://www.epa.gov/ostwater/oilgreas.html
EPA. 1998b. Integrated risk information system (IRIS). Online. National Center for Environmental Assessment, Cincinnati, OH. http://www.epa.gov/iris/subst/index.html
EPA. 1998c. Identification and listing of hazardous waste, definition of hazardous waste. U. S. Environmental Protection Agency, Washington, DC. Code of Federal Regulations. 40 CFR 261.3.
EPA. 1998d. Binational toxics strategy: stockholders forum November 16,1998. U.S. Environmental Protection Agency, Great Lakes National Program Office, Chicago.
Etkina EI, Etkina IA. 1995. Chemical mixtures exposure and children’s health. Chemosphere 31(1):2463–2474.7670860
Fahey JW, Zhang Y, Talalay P. 1997. Broccoli sprouts: An exceptionally rich source of inducers of enzymes that protect against chemical carcinogenesis. U.S. Proc Nat1 Acad Sci. 94:10367–10372.
Farrington JW, Teal JM, Quinn JG, 1973. Intercalibration of analyses of recently biosynthesized hydrocarbons and petroleum hydrocarbons in marine lipids. Bull Environ Contam Toxicol, vol 10(3):129–36.4753263
Farrington JW, Tripp BW, Teal JM, 1982. Biogeochemistry of aromatic hydrocarbons in the benthos of microcosms. Toxicol Environ Chem 5 (3-4):331–346.
Feenstra S, Makay DM, Cherry JA. 1991. A method for assessing residual NAPL based on organic chemical concentrations in soil samples. Ground Water Monitoring Review 11:128–136.
Firriolo JM, Morris CF, Trimmer GW, 1995. Comparative 90-day feeding study with low viscosity white mineral oils in Fischer 344 and Sprague-Dawley-derived CRL: CD rats. Toxicol Pathol 23:26–33.7770697
Fitzpatrick MG, Tan SS. 1993. Recent advances in the determination of total petroleum hydrocarbons in soil. Chemistry in New Zealand, 22.
Fowler SW, Readman JW, Oregioni B, 1993. Petroleum hydrocarbons and trace metals in nearshore Gulf sediments and biota before and after the 1991 war: An assessment of temporal and spatial trends. Marine Pollution Bulletin 27:171–182.
Frankenberger WT. 1992. The need for laboratory feasibility study in bioremediation of petroleum hydrocarbons. In: Calabrese E, Kostecki P, eds. Hydrocarbon contaminated soils and groundwater, vol 2. Chelsea, MI: Lewis Publishers, 237–293.
Friedman PA. 1987. Poisoning and its management. In: Jeffers JD, Scott EJ, Ramos-Englis M, eds. Harrison’s principles of internal medicine. Eleventh Edition. New York: McGraw-Hill, 838–850.
FSTRAC. 1990. Federal-state toxicology and regulatory alliance committee. Summary of state and federal drinking water standards and guidelines. U.S. Environmental Protection Agency. p. 16. February, 1990.
Gaworski CL, MacEwen JD, Vernot EH, 1984. Comparison of the subchronic inhalation toxicity of petroleum and oil shale JP-5 jet fuels. In: MacFarland HN, Holdsworth CE, MacGregor JA, eds. Advances in modern environmental toxicology. Volume VI: Applied toxicology of petroleum hydrocarbons. Princeton, NJ: Princeton Scientific Publishers, 33–47.
Gay ML, Belisle AA, Patton JF. 1980. Quantification of petroleum-type hydrocarbons in avian tissue. J Chromatogr 187(l):153–160.7358812
George S. 1992. Positive and negative bias associated with the use of EPA Method 418.1 for the determination of total petroleum hydrocarbons in soil. Environmental Science and Engineering, Inc.
Gere DR, Knip CR Castelli, Hendrick J 1993. Bridging the automation gap between sample preparation and analysis: An overview of SFE, GC-MS and HPLC applied to environmental samples. J Chromatogr Sci, 3 1(7):246–258.
Gidron E, Leurer J. 1956. Naphthalene poisoning. Lancet (February 4): 228–230.
Goodwin TM. 1988. Toluene abuse and renal tubular acidosis in pregnancy. Obstet Gynecol 71:715–718.3357661
Green JD, Leong BK J, Laskin S. 1978. Inhaled benzene fetotoxicity in rats. Toxicol Appl Pharmacol 46:9–18.725954
Guiney PD, Sykora JL, Kelett G. 1987. Qualitative and quantitative analyses of petroleum hydrocarbon concentrations in a trout stream contaminated by an aviation kerosene spill. Env Tox Chem 6:105–114.
Gustafson J. 1995. Personal communication with Mary Siedlecki, Research Triangle Institute.
Gustafson J. 1997. Using TPH in risk-based corrective action. Shell Development Corporation. Published on Internet by U.S. Environmental Protection Agency, Office of Underground Storage Tanks. http://www.epa.gov/swerustl/rbdm/tphrbca.htm
Haggerty RJ. 1956. Toxic hazards: Naphthalene poisoning. The New England Journal of Medicine 255: 919–920.
Hansch C, Leo A. 1979. Substituent constants for correlation analysis in chemistry and biology. New York, NY: John Wiley and Sons.
Hansen H, De Rosa CT, Pohl H, Fay M, Mumtaz MM. 1998. Public health challenges posed by chemical mixtures. Environ Health Persp 106:1271–1280.
Hass U, Jakobsen BM. 1993. Prenatal toxicity of xylene inhalation in the rat: A teratogenicity and postnatal study. Pharmacology and Toxicity 73:20–23.
Hasty E, Revesz F. 1995. Total petroleum hydrocarbon determination by microwave solvent extraction. American Laboratory 27(4):66.
Havlicek SC. 1988. Characterization of fuels an fuel spills. Central coast analytical services, San Louis Obispo, California.
Hawthorne ST, Miller DJ, Hegvik KM. 1993. Field evaluation of the SFE-infrared method for total petroleum hydrocarbon (TPH) determinations. Journal of Chromatographic Science 31:26–30.
HazDat. 1999. Database. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA.
Heath JS, Koblis K, Sager SH. 1993a. Risk assessment for total petroleum hydrocarbons. Chapter 16. In: Kostecki P, Calabrese E. eds. Hydrocarbon contaminated soils. Chelsea, MI: Lewis Publishers, 267–301.
Heath JS, Koblis K, Sager SH. 1993b. Review of chemical, physical, and toxicological properties of components of TPH. J Soil Contam, 2(1):1–25.
Hersh JH. 1989. Toluene embryopathy: Two new cases. J Med Genet 26:333–337.2471833
Hersh JH, Podruch PE, Rogers G, 1985. Toluene embryopathy. J Pediatr 106:922–927.4039753
Howd RA, Rebert CS, Dickinson J, 1983. A comparison of the rates of development of functional hexane neuropathy in weanling and young adult rats. Neurobehav Toxicol Teratol 5:63–68.6304548
Hseih GC, Sharma RP, Parker RD. 1989. Immunological evaluation of toluene exposure via drinking water in mice. Environ Res 49:93–103.2785914
Hunter AG W, Thompson D, Evans JA. 1979. Is there a fetal gasoline syndrome? Teratology 20:75–79.515965
Hutcheson MS, Pedersen D, Anastas ND, Fitzgerald J, Silverman D. 1996. Beyond TPH: Health-based evaluation of petroleum hydrocarbon exposures. Reg Toxicol Pharmacol 24:85–101.
IARC. 1984. Mineral oils. IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans. International Agency for Research on Cancer. 33:87–168.
IARC. 1985. Polynuclear aromatic compounds. Part 4, Bitumens, coal-tars and derived products, shaleoils and soots. IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans. International Agency for Research on Cancer. 35:39–81.
IARC. 1987. Mineral oils: Untreated and mildly-treated oils (Group 1), highly-refined oils (Group 3). IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans. International Agency for Research on Cancer. Supplement 7:252–259.
IARC. 1989a. Gasoline. IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans. International Agency for Research on Cancer. 45:159–201.
IARC. 1989b. Fuel oils (heating oils). IARC monographs on the evaluation of carcinogenic risks to humans. International Agency for Research on Cancer. 45:239–270.
IARC. 1989c. Crude oil. IARC monographs on the evaluation of the carcinogenic risks of chemicals to humans. International Agency for Research on Cancer. 45:119–158.
IARC. 1989d. Jet fuels. IARC monographs on the evaluation of carcinogenic risks to humans. International Agency for Research on Cancer. 45:203–237.
IARC. 1989e. IARC monographs on the evaluation of the carcinogenic risks of chemicals to humans. International Agency for Research on Cancer. 45:39–117.
IARC. 1989f. IARC monographs on the evaluation of carcinogenic risks to humans. Vol. 47: Some organic solvents, resin monomers and related compounds, pigments and occupational exposures in paint manufacturing and painting. Lyon, France: World Health Organization, International Agency for Research on Cancer.
IARC. 19898. IARC monographs on the evaluation of the carcinogenic risks of chemicals to humans. International Agency for Research on Cancer. 35:39–81.
IARC. 1996. Cumulative cross index to IARC Monograph on the evaluation of carcinogenic risks to humans. International Agency for Research on Cancer. 66:487–514.
IRDC. 1981. Six-month continuous inhalation exposure of rats to hexane mixtures-Phase II. Unpublished study by International Research and Development Corporation, Mattawa MI. Prepared for the American Petroleum Institute, Washington DC. EPA FYI-AX-0282-0166 Addendum.
Jensen K. 1977. Sources and routes of removal of petroleum hydrocarbons in a Danish marine inlet. Oil and Petroleum Production, 1(3):207–216.
Johnson B, De Rosa CT. 1995. Chemical mixtures released from hazardous waste sites: Implications for health risk assessment. Toxicol 105:145–56.
Barry Johnson, Andrews JS Jr., Xintaras C, Mehh-nan MA, eds. 1998. Advances in modem environmental toxicology. Vol. XXV. Hazardous waste: Toxicology and health effects. Princeton, NJ: Princeton Scientific Publishing, Inc.
Jordan RE, Payne JR. 1980. Fate and weathering of petroleum spills in the marine environment: A literature review and synopsis. Ann Arbor, MI: Ann Arbor Science Publisher, Inc.
Judge C, Kostecki P, Calabrese E. 1997. State summaries of soil cleanup standards. Soil and Groundwater Cleanup. November, pp. 10–34.
Judge C, Kostecki P, Calabrese E. 1998. State by state groundwater standards. Soil and Groundwater Cleanup. May, pp. 11–31.
Kainz RJ, White LE. 1984. Depressant effects associated with the inhalation of uncombusted diesel vapor. In: MacFarland HN, Holdsworth CE, MacGregor JA, eds. Advances in modern environmental toxicology. Volume VI: Applied toxicology of petroleum hydrocarbons. Princeton, NJ: Princeton Scientific Publishers, Inc.
Kelly DW, Duffy JS, Haddock LX, 1994. Chronic inhalation study of commercial hexane in rats. Toxicologist 14:317 (Abstract #1233).
Kimura K, Nagata T, Kudo K, 1991. Determination of kerosene and light oil components in blood. Biol Mass Spectra, 20:493–497.
Kinkead ER, Haun CC, Schneider MG, 1985. Chronic inhalation exposure of experimental animals to methylcyclohexane. Govt Reports Announcements and Index, Issue 21.
Klaasen CD. 1996. Nonmetallic environmental toxicants. Air pollutants, solvents and vapors, and pesticides. In: Hardman JG, Limbird LE, eds. Goodman and Gilman’s The pharmacological basis of therapeutics. 9th Edition. New York,NY: McGraw-Hill.
Knox RC. 1993. Spatial moment analysis for mass balance calculations and tracing movement of a subsurface hydrocarbon mound. Ground Water Monitoring & Remediation, 13(3):139–147.
Koblis K, Day C, Heath J. 1993. Impact of surrogate selection on risk assessment for total petroleum hydrocarbons. Journal of Soil Contamination, 2(2):125–136.
Legaverend C, Guenther TM, Nebert DW. 1984. Importance of the route of administration for genetic differences in benzo(a)pyrene-induced in utero toxicity and teratogenicity. Teratology 29:35–47.
Li L, Sun W, Gong Z, 1992. Effect of low benzene exposure on neurobehavioral function, AChE in blood and brain and bone marrow picture in mice. Biomed Environ Sci 5(4):349–354.1489529
Lindemann R. 1991. Congenital renal tubular dysfunction associated with maternal sniffing of organic solvents. Acta Pediatr Stand 80:882–884.
Lioy PJ. 1992. General summary and recommendations of the workshop on general population exposures to gasoline. J Expo Anal Environ Epidemiol 2(1):5–8.1504634
Bionetics Litton. 1978. Teratology study in rats: Unleaded gasoline. Final report submitted to American Petroleum Institute, Washington, DC. Kensington, MD: Litton Bionetics, Inc.
Lodge JP Jr, ed. 1988. Methods of air sampling and analysis. Lewis Publishers, Inc., 262–264.
Lopez-Avila V, Young R, Kin R, 1993. Interlaboratory evaluation of an off-line supercritical fluid extraction/infrared spectrometric method for determination of petroleum hydrocarbons in solid matrixes. JAOAC Int 76(3):555–562.
Lopez-Avila V, Young R, Beckert WF. 1994. Microwave-assisted extraction of organic compounds from standard reference soils and sediments. Analytical Chemistry, 66(7):1097–1106.
LUFT. 1988. Leaking underground fuel tank manual: Guidelines for site assessment, Cleanup, and underground storage tank closure. State of California Leaking Underground Fuel Tank Force, May 1988. Sacramento California.
Lyman WJ, Noonan DC, Reidy PJ. 1990. Cleanup of petroleum contaminated soils at underground storage tanks. Noyes Data Corporation, Park Ridge, New Jersey.
MacFarland I-IN Holdsworth CE, MacGregor JA, eds. 1984a. Applied toxicology of petroleum hydrocarbons. Advances in modem environmental toxicology. Vol. VI. Princeton, NJ: Princeton Scientific Publishing, Inc.
MacFarland I-IN, Ulrich CE, Holdsworth CE, 1984b. A chronic inhalation study with unleaded gasoline vapor. J Amer Col1 Toxicol 3:231–248.
Mackay D. 1984. Chemical and physical behavior of hydrocarbons in freshwater. In: Vandermeulen Hrudey SE, eds., Oil in freshwater: Chemistry, biology, countermeasure technology. New York: Pergamon Press, 85–94.
Mackay D. 1988. The chemistry and modeling of soil contamination with petroleum. In: Calabrese E, Kostecki P, eds. Soils contaminated by petroleum. New York, NY: John Wiley and Sons, 5–18.
MADEP. 1994. Interim final petroleum report: development of health-based alternative to the total petroleum hydrocarbon (TPH) parameter. Massachusetts Department of Environmental Protection, Bureau of Waste Site Cleanup. August 1994.
MADEP. 1996. Issues paper: Implementation of the VPH/EPH approach. Public comment draft. Massachusetts Department of Environmental Protection, Bureau of Waste Site Cleanup, Boston, MA. May 1996.
MADEP. 1997. Characterizing risks posed by petroleum contaminated sites: implementation of MADEP VPH/EPH Approach, public comment draft. Massachusetts Department of Environmental Protection, Bureau of Waste Site Cleanup, Boston, MA. October 31, 1997.
MADEP. 1999. Massachusetts Department of Environmental Protection. http://www.state.ma.us/dep.
Mahdi AH. 1988. Kerosene poisoning in children in Riyadh. J Trop Pediatr 34(6):316–318.3221417
Marks TA, Ledoux TA, Moore JA. 1982. Teratogenicity of a commercial xylene mixture in the mouse. J Toxicol Environ Health 9:97–105.7062354
MARPOL. 1978. International convention for prevention of pollution from ships (MARPOL). 1978 Protocol: Annexes I-V - Oil, Noxious Liquids, etc.
Martin MJ. 1992. Sonication vs. Soxhlet extraction for soil analysis. Environ Lab, June/July, 34–35.
Mattie DR, Marit GB, Flemming CD, Cooper JR. 1995. The effects of JP-8 jet fuel on male Sprague-Dawley rats after a 90-day exposure by oral gavage. Toxicol Ind Health 11:423–435.8748423
McDonald TJ, Brooks JM, and Kennicut MC. 1984. Release of volatile liquid hydrocarbons from spilled petroleum. Bull Contam Toxicol 32(5):621–628.
McMurray WC. 1977. Essentials of human metabolism. 2”d ed. Philadelphia, PA: Harper & Row, 252–254.
Mehhnan MA, ed. 1983. Carcinogenicity and toxicity of benzene. In: Advances in modern environmental toxicology. Vol. IV. Princeton, NJ: Princeton Scientific Publishing, Inc.
Mehlman MA, ed. 1989. Benzene: Occupational and environmental hazards - scientific update. In: Advances in modem environmental toxicology. Vol. XVI. Princeton, NJ: Princeton Scientific Publishing, Inc.
Mehlman MA, ed. 1991. Health hazards and risks from exposure to complex mixtures and air toxic chemicals. In: Advances in modem environmental toxicology. Vol. XIX. Princeton, NJ: Princeton Scientific Publishing, Inc.
Mehlman MA, ed. 1992. Dangerous and cancer-causing properties of products and chemicals in the oil refining and petrochemical industry: VII. Health effects of motor fuels: carcinogenicity of gasoline scientific update. Environmental Research 59:238–240.
Mehlman MA. 1996. Dangerous and cancer-causing properties of products and chemicals in the oil refining and petrochemical industry: XI. Carcinogenicity and environmental hazards of crude oil, gasoline, and its components. J Clean Technol, Environ Toxicol, and Occup Med 5(2)115–130.
Mehlman MA, Henstreet CP II I, Thorpe JJ, Weaver NK, eds. 1984. Renal effects of petroleum hydrocarbons. In: Advances in modern environmental toxicology. Vol. VII. Princeton, NJ: Princeton Scientific Publishing, Inc.
Mehhnan MA, Upton A, eds. Identification and control of environmental and occupational diseases: Hazards and risks of chemical sin the oil refining industry. Vol. XXIII. Princeton, NJ: Princeton Scientific Publishing, Inc.
Miller MJ, Lonardo EC, Greer RD, 1996. Variable responses of species and strains to white mineral oils and paraffin waxes. Reg Toxicol Pharmacol 23:55–68
Mills SA, Frankenberger WT Jr. 1994. Evaluation of phosphorus sources promoting bioremediation of diesel fuel in soil. Bull Environ Contam Toxicol 53(2):280–4.8086712
Mumtaz MM, De Rosa C, Durkin PR. 1994. Approaches and challenges in risk assessments of chemical mixtures. In: Toxicology of chemical mixtures. New York, NY: Academic Press, 565–597.
Mumtaz MM, Durkin PR. 1992. A weight of evidence scheme for assessing interactions in chemical mixtures. Toxicol Indust Health 8:377–406.
Mumtaz MM, Poirier KA, Colman JT. 1997. Risk assessment for chemical mixtures: Fine-tuning the hazard index approach. J Clean Technol, Environ Toxicol & Occup Med 6(2):189–204.
Murray DA, Lockhart WL. 1981. Microextraction and gas chromatographic analysis of selected petroleum hydrocarbons in water and fish tissue. J Chromatogr 212(3):305–11.7263799
Murray KS. 1994. The TRPH controversy. American Laboratory, October, 1994. p. 8.
Murray FJ, John JA, Rampy LW, 1979. Embryotoxicity of inhaled benzene in mice and rabbits. Am Ind Hyg Assoc J 40:993–998.532786
Mushrush GW, Mose DG, and Sullivan KT. 1994. Soil vapor and groundwater analysis from a recent oils spill. Bull Environ Contam Toxicol 52:31–38.8130414
NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
NATICH 1992. National air toxics information clearinghouse. NATICH data base report on state, local and EPA air toxics activities. Final. U.S. Environmental Protection Agency. EPA 453/R-92-008. Pp. 4-87, 4-120, 4-121, 4-171, and 4-189. September 1, 1992.
NIOSH. 1992. NIOSH recommendations for occupational safety and health. Compendium of policy documents and statements. U.S. Department of Health and Human Services. Cincinnati, Ohio. Page 85. January, 1992.
NIOSH. 1994. NIOSH manual of analytical methods. 4^th^ ed. U.S. Department of Health and Human Services.
NTP. 1991. Developmental toxicity of naphthalene (CAS No. 91-20-3) administered by gavage to Sprague-Dawley (CD) rats on gestational days 6 through 15. Research Triangle Park, NC: National Toxicology Program, National Institute of Environmental Health Sciences, U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. TER-91006.
NTP. 1992. National Toxicology Program. Technical report series No. 410. Toxicology and carcinogenesis studies of naphthalene (CAS No. 91-20-3) in B6C3F, mice (inhalation studies). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. NIH Publication No. 92-3141.
NTP. 1996. Toxicology and carcinogenesis studies of ethylbenzene in F344/N rats and B6C3Fl mice. (Inhalation Studies). National Toxicology Program. TR-466. Draft.
OHM/TADS. 1985. Oil and Hazardous Materials/Technical Assistance Data System. Baltimore, MD: Chemical Information Systems, Inc. December 1985.
Orbaek P, Nise G. 1989. Neurasthenic complaints and psychometric function of toluene-exposed rotogravure printers. Am J Ind Med 16:67–77.2750752
OSHA. 1974. Limits for air contaminants: Petroleum distillates. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000.
Pancirov R. J. and Brown R. A.. 1975. Analytic methods for polynuclear aromatic hydrocarbons in crude oils, heating oils, and marine tissues. In: Proceedings of the 1975 Conference on Prevention and Control of Oil Pollution, March 25-27, 1975. San Francisco, CA. American Petroleum Institute: Washington, DC., 103-l 14.
Park KS, Sims RC, DuPont RR, 1990. The fate of PAH compounds in two soil types: Influence of volatilization of abiotic loss and biological activity. Environ Toxicol Chem 9(2):187–196.
Pedersen LM, Larsen K, Cohr K. 1984. Kinetics of white spirit in human fat and blood during short-term experimental exposure. Acta Pharmacol. Toxicol 55:308–316.
Pedersen LM, Rasmussen S, Cohr C. 1987. Further evaluation of the kinetics of white spirit in human volunteers. Pharmacol Toxicol 60:135–137.3575247
Pellizzari ED, Hartwell TD, Harris BS, 1982. Purgeable organic compounds in mothers milk. Bull Environ Contam Toxicol, 28(3):322–328.7082873
Pellizzari ED, Wallace LA, Gordon SM. 1992. Elimination kinetics of volatile organics in humans using breath measurements. J Expo Anal Environ Epidemiol, 2(3):341–55.1422163
PennWell. 1994. Energy statistics sourcebook, 9th Edition. Tulsa, OK: Oil & Gas Journal Energy Database Publications, PennWell Publishing Company.
PennWell. 1998. Energy statistics sourcebook, 13th Edition. Tulsa, OK: Oil & Gas Journal Energy Database Publications, PennWell Publishing Company.
Phillips RD, Eagan GF. 1984. Subchronic inhalation exposure of dearomatized white spirit and Cl0-Cl1 isoparaffinic hydrocarbon in Sprague-Dawley rats. Fund Appl Toxic 4:808–818.
Picer M, Picer N. 1993. Evaluation of modification o the simple spectrofluorimetry method for estimating petroleum hydrocarbon levels in sea water. Bull Environ Contam Toxicol 50(6):802–810.8495055
Potter TL. 1993. Analysis of petroleum contaminated soil and water: An overview. In: Calabrese EJ, Kostecki PT, eds. Principles and practices for petroleum contaminated soils, 1–14. Ann Arbor, MI: Lewis Publishers.
Prochaska HJ, Talalay P. 1992. Phenolic antioxidants as inducers of anticarcinogenic enzymes. In: Huang M-T, Ho C-T, Lee CY, eds. Phenolic compounds in food and their effects on health. Vol. II. 150–159. American Chemical Society Symposium Series No. 507.
Pykko K. 1983. Time-course of effects of toluene on microsomal enzymes in rat liver, kidney and lung during and after inhalation exposure. Chem Biol Interact 44:299–310.6409435
Restek Corporation. 1994. Guide for the analysis of petroleum hydrocarbons in soil and water. Restek Corporation, Bellafonte, Pennsylvania.
Rhodes IA, Hinojosa EM, Barker DA, 1995/1996. Determination of total petroleum hydrocarbons by capillary gas chromatography. Shell Development Company, Environmental Analysis Department, Houston.
Rozen MG, Snyder CA, Albert RE. 1984. Depression in B- and T-lymphocyte mitogen-induced blastogenesis in mice exposed to low concentrations of benzene. Toxicol Lett 20:343–349.6608167
Runion HE. 1988. Occupational exposures to potentially hazardous agents in the petroleum industry. Occupational Medicine: State of the Art Reviews 3(3):431–444.
Santhanakrishnan BR, Chithra S. 1978. Accidental kerosene poisoning in infants and children. Indian J Pediatr 45(367):265–273.730290
Schafer WB. 1951. Acute hemolytic anemia related to naphthalene: Report of a case in a newborn infant. Pediatrics &; 172–174.
Schlien HH. 1992. Physical and chemical characteristics of mineral oils. CONCAWE/DGMK Scientific Seminar; Remediation of oil spills, May 18-21, 1992.
Schrynemeeckers R. 1993. Immunoassay in the environmental industry. Environ Testing & Analysis 2(1)56–60.
Shendrikova IA, Aleksandrov VA. 1974. Comparative penetration of polycyclic hydrocarbons through the rat placenta into the fetus. Bull Exp Biol Med 77:169–171.4433923
Shopp GM, White KL Jr, Holsapple MP, 1984. Naphthalene toxicity in CD-l mice: General toxicology and immunotoxicology. Fundam Appl Toxicol 4:406–419.6745531
Smith JH, Mallett AK, Priston RAJ, 1996. Ninety-day feeding study in Fischer-344 rats of highly refined petroleum-derived food-grade white oils and waxes. Toxicol. Pathol. 24:214–130.8992612
Snodgrass WR. 1997. Clinical Toxicology. In: Klaassen CD, Amdur MO, Doull J, eds. Cassarett and Doull’s toxicology. The basic science of poisons. Fifth Edition. New York, NY: McGraw-Hill, 969-986.
Speight JG. 1991. The chemistry and technology of petroleum 2nd edition. New York,NY: Mercel Dekker. Inc.
John MA St. 1982. Kerosene poisoning in children in Barbados. Ann Trop Paediatr 2( 1):37–40.6186189
Starek A, Vojtisek M. 1986. Effects of kerosene hydrocarbons on tissue metabolism in rats. Pol J Pharmacol Pharm 38(5-6):461–469 3575166
Steimle FW, Boehm PD, Zdanowicz VS, 1986. Organic and trace metal levels in ocean quahog Arctica islandica from the northwestern Atlantic. U.S. Nat Mar Fish Serv Fish Bull, 84( 1):133–140.
Stelljes ME, Watkin GE. 1991. Comparison of environmental impacts posed by different hydrocarbon mixtures: a need for site-specific composition analyses. Hydrocarbon Contam Soils Groundwater, 3:549-69
Stelljes ME, Watkin GE. 1993. Comparison of environmental impacts posed by different hydrocarbon mixtures: a need for site-specific composition analysis. In: Kostecki P, Calabrese E, eds. Hydrocarbon contaminated soils and groundwater, Vol 3. Chelsea, MI: Lewis Publishers, 549–570.
Stevens P, ed. 1988. Oil and gas dictionary. New York, NY: Nichols Publishing.
Talalay P. 1992. The role of enzyme induction in protection against carcinogenesis. In: Wattenberg L, Lipkin M, Boone CW, Kelloff GJ, eds. Cancer chemoprevention. Boca Raton, FL: CRC Press, 469–478.
Tan YA, Kuntum A. 1994. Hydrocarbons in crude palm kernel oil. JAOAC Int 77(1):67–73.
Tatrai E, Rodrics K, Ungvary G. 1980a. Embryotoxic effects of simultaneously applied exposure of benzene and toluene. Folia Morph01 (Praha) 28:286–289.
Tatrai E, Ungvary GY, Hudak A, 1980b. Concentration dependence of the embryotoxic effects of benzene inhalation in CFY rats. J Hyg Epidemiol Microbial Immunol 24:363–371.
Thomas KW, Pellizzari ED, Cooper SD. 1991. A canister-method for collection and GC/MS analysis of volatile organic compounds in human breath. J Anal Toxicol, 15(2):54–59.2051745
Todd GD, Hansen HJ, Mehlman MA, De Rosa CT. 1999. The public health challenges of total petroleum hydrocarbons (TPH). Environ Epi Toxicol. In press.
TPHCWG. 1997a. A risk-based approach for the management of total petroleum hydrocarbons in soil. Total petroleum hydrocarbon criteria working group. March 1997. http://www.aehs.com.
TPHCWG. 1997b. Total petroleum hydrocarbon criteria working group series, volume 3. Selection of representative TPH factions based on fate and transport considerations. Gustafson J, Tell JG, Orem D, eds. Amherst, MA: Amherst Scientific Publishers.
TPHCWG. 1997c. Total petroleum hydrocarbon criteria working group series, volume 4. Development of fraction specific reference doses (RfDs) and reference concentrations (RfCs) for total petroleum hydrocarbons (TPH). Edwards DA, Amoroso MD, Tummey AC, eds. Amherst, MA: Amherst Scientific Publishers.
TPHCWG. 1998a. Total petroleum hydrocarbon criteria working group series, volume 1. Analysis of petroleum hydrocarbons in environmental media. Weisman W, ed. Amherst, MA: Amherst Scientific Publishers.
TPHCWG. 1998b. Total petroleum hydrocarbon criteria working group series, volume 2. Composition of petroleum mixtures. Potter TL, Simmons K, eds. Amherst, MA: Amherst Scientific Publishers.
Uchida Y, Nakatsuka H, Ukai H, 1993. Symptoms and signs in workers exposed predominantly to xylenes. Int Arch Occup Environ Health 64597–605.
Ungvary G. 1985. The possible contribution of industrial chemicals (organic solvents) to the incidence of congenital defects caused by teratogenic drugs and consumer goods: An experimental study. In: Marois M, ed. Prevention of physical and mental congenital defects. Part B: Epidemiology, early detection and therapy, and environmental factors. New York: Alan R. Liss, Inc., 295–300.
Ungvary G, Tatrai E. 1985. On the embryotoxic effects of benzene and its alkyl derivatives in mice, rats, and rabbits. Arch Toxicol [Supplement to] 8:425–430.
Ungvary G, Tatrai E, Hudak A, 1980b. Studies on the embryotoxic effects of ortho-, meta, and para-xylene. Toxicology 18:61–74.7210024
Ungvary G, Varga B, Horvath E, 1981. Study on the role of maternal sex steroid production and metabolism in the embryotoxicity of para-xylene. Toxicology 19:263–268.7233451
Urso P, Gengozian N. 1980. Depressed humoral immunity and increased tumor incidence in mice following in utero exposure to benzo(a)pyrene. J Toxicol Environ Health 6:569–576. -7420464
Urso P, Johnson RA. 1987. Early changes in T lymphocytes and subsets of mouse progeny defective as adults in controlling growth of a syngeneic tumor after in utero insult with benzo(a)pyrene. Immunopharmacology 14:1–10.3500149
Valaes T, Doxiadis SA, Fessas P. 1963. Acute hemolysis due to naphthalene inhalation. J Pediatr 63:904–915.14071045
Verhaar HJ M, Morroni JR, Reardon KF, 1997. A proposed approach to study the toxicology of complex mixtures of petroleum products: The integrated use of QSAR, lumping analysis and PBPWPD modeling. Environ Health Perspect 105:179–195.9114286
Wanless IR, Geddie WR. 1985. Mineral oil lipogranulomata in liver and spleen. Arch Pathol Lab Med 109:283–286.3838459
WHO. 1982. Selected petroleum products, environmental health criteria 20. IPCS International Programme on Chemical Safety. World Health Organization, Geneva.
Wilkins-Haug L, Gabow PA. 1991. Toluene abuse during pregnancy: Obstetric complications and perinatal outcomes. Obstet Gynecol 77:504–509.2002970
Wilson BH, Armstong JM, Wilson JT, 1991. Biotransformation of monoaromatic chlorinated hydrocarbons at an aviation gasoline spill site. Geomicrobiology Journal 8:225–240.
Wilson JT, McNabb JF, Cochran JW, 1985. Influence of microbial adaptation on the fate of organic pollutants in groundwater. Environmental Toxicology and Chemistry 4(6):721–726.
Williams UP, Kiceniuk JW, Fancey LL, 1989. Tainting and depuration of taint by lobsters (Homarus americanus) exposed to water contaminated with a no. 2 fuel oil: Relationship with aromatic hydrocarbon content in tissue. J Food Sci 54(2):240–243.
Xiang Y, Morgan SL, Watt BE. 1995. TPH and BTEX quantitation in gasoline and diesel contaminated soils by capillary gas chromatography-mass spectrometry. J Chromatographic Science 33:98–108.
Youngren SH, McKenna EA, Piccin TB, 1994. Evaluation of the total petroleum hydrocarbon standard at jet fuel contaminated Air Force sites. Final Report, Brooks Air Force Base, Texas.
Zahlsen K, Eide I, Nilsen AM, 1992. Inhalation kinetics of C_6_ to C_10_ aliphatic, aromatic and naphthenic hydrocarbons in rat after repeated exposures. Pharmacol Toxicol 71:144–149.1438030
Zhang Y, Talalay P, Cho C- G, 1992. A major inducer of anticarcinogenic protective enzymes from broccoli: Isolation and elucidation of structure. US Proc Nat1 Acad Sci 89:2399–2403.
Zinkham WH, Childs B. 1957. Effect of vitamin K and naphthalene metabolites on glutathione metabolism of erythrocytes from normal newborns and patients with naphthalene hemolytic anemia. Am J Dis Child 94: 420–423.
Zinkham WH, Childs B. 1958. A defect of glutathione metabolism of erythrocytes from patients with naphthalene-induced hemolytic anemia. Pediatrics 22:461–471.13578538