# APPENDIX E IDENTITY, COMPONENTS, AND CHEMICAL/PHYSICAL PROPERTIES OF SELECTED PETROLEUM PRODUCTS

TPH is a value that represents the amount of petroleum hydrocarbons in a given sample, as previously presented in Section 2.1. There are far more than 250 individual chemicals that are known as petroleum hydrocarbons. Some of these are listed in Appendix D. More often, many of the petroleum hydrocarbons are known by the names associated with the more common whole petroleum products, such as gasoline, fuel oil, mineral oil, and jet fuels, for example. These whole products are actually mixtures of numerous individual compounds, such as those listed in Appendix D, as well as, sometimes, non-petroleum hydrocarbon additives. Because of the complexity involved in chemically and physically describing and categorizing these whole products this Appendix contains more detailed information about the more prominent products that are likely to be associated with TPH. A list of the information is given below.

E-1 Automotive Gasoline
  A. Chemical Identity
  B. Composition
  C. Chemical and Physical Properties
E-2 Stoddard Solvent
  A. Chemical Identity
  B. Composition
  C. Chemical and Physical Properties
E-3 JP-4
  A. Chemical Identity
  B. Composition
  C. Chemical and Physical Properties
E-4 Fuel Oil
  A. Chemical Identity
  B. Composition
  C. Chemical and Physical Properties
E-5 Crankcase Oils, Mineral-based
  A. Chemical Identity
  B. Composition
  C. Chemical and Physical Properties
E-6 Mineral Oil
  A. Chemical Identity
  B. Chemical and Physical Properties

Table E-1.a Chemical Identity of Gasoline^a^

Character | Information | Reference
Chemical Name | Gasoline | RTECS 1995
Synonym (s) | Casing head gasoline, natural gasoline petrol, motor fuel, motor spirit | RTECS 1995; ATSDR 1995a
Identification Numbers:
CAS Registry | 8006-61-9 | RTECS 1995
NIOSH RTECS | LX3300000 | RTECS 1995
EPA Hazardous Waste | No data
OHM/TADS | 7217073 | OHM/TADS 1991
DOT/UN/NA/IMCO shipping | UN1203, UN1257 | RTECS 1995
HSDB | No data
NCI | No data

a Gasoline is a mixture of C-4 through C-12 hydrocarbons, primarily consisting of 4–8% alkanes, 2–5% alkenes, 25–40% isoalkanes, 3–7% cycloalkanes, 1–4% cycloalkenes, and 20–50% aromatics.

Source: ATSDR (1995a)

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data Systems; RTECS = Registry of Toxic Effects of Chemical Substances

Table E-1.b Major Hydrocarbon Components of Gasoline

Fraction Compound | Gasoline Weight Percent Range | Gasoline Weight Percent Mean
C6 Aromatics
Benzene | 0.12–3.50 | 2.34
C3–C6 Aliphatic
Propane | 0.01–0.14 | 0.00666
n-Butane | 3.93–4.70 | 3.57
Isobutane | 0.12–0.37 | 0.316
n-Pentane | 5.75–10.92 | 3.18
n-Hexane | 0.24–3.50 | 2.61
2,2-Dimethylbutane | 0.17–0.84 | 0.304
2,3-Dimethylbutane | 0.59–1.55 | 1.41
Neopentane | 0.02–0.05
Isopentane | 6.07–10.17 | 6.22
2-Methylpentane | 2.91–3.85 | 3.35
3-Methylpentane | 2.4 (vol) | 2.14
Cyclopentane | 0.19–0.58 | 0.131
Methylcyclopentane | not quantified | 2.08
Cyclohexane | | 0.722
1-Pentene | 0.33–0.45 | 0.222
1-Pentyne
cis-2-Pentene | 0.43–0.67 | 0.865
1-Hexene | | 0.22
1-Hexyne
3-Methyl-1-butene | 0.08–0.12 | 0.417
2-Methyl-1-Pentene | 0.20–0.22 | 0.258
Cyclopentene | 0.12–0.18 | 0.236
Cyclohexene | 0.03
C7–C8 Aromatics
Toulene | 2.73–21.80 | 8.21
Ethylbenzene | 0.36–2.86 | 1.9
o-Xylene | 0.68–2.86 | 2.71
m-Xylene | 1.77–3.87 | 3.5
p-Xylene | 0.77–1.58 | 3.5
Styrene
C7–C8 Aliphatics
n- Heptane | 0.31–1.96 | 1.14
n-Octane | 0.36–1.43 | 0.426
2,2,3-Trimethylbutane | 0.01–0.04 | 0.025
2,2-Dimethylpentane | 0.25 | 0.0878
2,4-Dimethylpentane | 0.23–1.71 | 0.734
2,3-Dimethylpentane | 0.32–4.17 | 1.54
3,3-Dimethylpentane | 0.02–0.03 | 0.0989
2,2,4-Trimethylpentane | 0.32–4.58 | 1.64
2,3,4-Trimethylpentane | 0.11–2.80 | 0.519
2-Methylhexane | 0.36–1.48 | 1.44
3-Methylhexane | 0.30–1.77 | 1.5
2-Methylheptane | 0.48–1.05 | 0.614
3-Methylheptane | 0.63–1.54 | 0.647
1,1,3-Trimethycyclo-pentane | 0.3 | 0.0511
1-Trans-2-trans-4-Trimethylcyclopentane
n-Propylcyclopentane | 0.01–0.06
1-Trans-2-dimethylcyclohexane
1-Trans-4-dimethylcyclohexane | | 0.142
Methylcyclohexane | | 0.611
Trans-2-heptene | 0.06–0.10 | 0.105
1-Octene | | 0.101
C9–C10 Aromatics
1-Methyl-4-ethylbenzene | 0.18–1.00 | 0.837
1-Methyl-2-ethylbenzene | 0.19–0.56 | 2.89
1-Methyl-4-isopropylbenzene
1,2,3-trimethylbenzene | 0.21–0.48 | 0.766
1,2,4-trimethylbenzene | 0.66–3.30 | 3.41
1,3,5-trimethylbenzene | 0.13–1.15 | 1.14
1,2,4,5-tetramethyl-benzene | 0.05–0.67
n-Propylbenzene | 0.08–0.72 | 0.648
Isopropylbenzene | <0.01–0.23
n-Butylbenzene | 0.04–0.44
Isobutylbenzene | 0.01–0.08
sec-Butylbenzene | 0.01–0.13
t-Butylbenzene | 0.12
Indan | 0.25–0.34
Tetralin (tetrahydronaphthalene) | 0.01–0.14
Naphthalene | 0.09–0.49
C9–C10 Aliphatics
n-Nonane | 0.07–0.83 | 0.243
n-Decane | 0.04–0.50 | 0.26
2,2,5-Trimethylhexane | 0.17–5.89 | 0.177
4-Methyloctane | 0.11–0.55 | 0.5
1,1,3-Trimethylcyclo-hexane
Pentylcyclopentane
1-Nonene
1-Decene
C11–C12 Aromatics
n-Pentylbenzene | 0.01–0.14
n-Hexylbenzene
Biphenyl
Acenaphthene
Acenaphthylene
1-Methylnaphthalene
1,4-Dimethyl-naphthalene
2,3-Dimethyl-naphthalene
2,6-Dimethylnaphthalene
1-Ethylnaphthalene
2-Ethylnaphthalene
C11-C12 Aliphatics
n-Undecane | 0.05–0.22
n-Dodecane | 0.04–0.09
C13-C16 Aromatics
Fluorene
Fluoranthene
1,4,5-Trimethylnaphthalene
Anthracene
9-Methyl anthracene
Phenanthrene
Pyrene | Not quantified
C13-C16 Aliphatics
n-Tetradecane
n-Hexadecane
C17–and up Aromatics
Benz(k)fluoranthene
Benz(a)anthracene | Not quantified
Chrysene
Triphenylene
Benzo(a)pyrene | 0.19–2.8 mg/kg
Benz(e)pyrene | Not quantified
Perylene
3-Methylcholanthrene
Benz(ghi)perylene | Not quantified
1,2,5,6-dibenz anthracene
C17–and up Aliphatics
n-Octadecane
n-Eicosane

Source: Table taken from EA Engineering 1995, Total Petroleum Hydrocarbon Criteria, Working Group Project #3, Based on Fate and Transport Considerations, Prepared for Armstrong Laboratory, Brooks Air Force Base, Occupational Medicine, Brooks Air Force Base, Texas, Prepared by EA Engineering, Science, and Technology, Lafayette, California.

Table E-1c Physical and Chemical Properties of Gasoline

Property | Information | Reference
Molecular weight | 108^a^ | ATSDR 1995a
Color | Colorless to pale brown | Sax and Lewis 1989
Physical state | Liquid | Sax and Lewis 1989
Melting point | No data
Boiling point | Initially, 39 °C | Sax and Lewis 1989
| After 10% distilled, 60 °C
| After 50% distilled, 110 °C
| After 90% distilled, 170 °C
| Final boiling point, 204 °C
Density | 0.7–0.8 g/cm^3^ ^b^ | IARC 1998
Odor | Gasoline | Weiss 1986
Odor threshold | 0.025 ppm ^c^ | Weiss 1986
Solubility
Water at 20 °C | Insoluble | Sax and Lewis 1989
Organic solvent(s) | Absolute alcohol, ether, chloroform, benzene | Sax and Lewis 1989
Partition coefficients
Log K_ow_ | 2.13–4.87^d^ | U.S. Air Force 1989
Log K_oc_ | 1.81–4.56^d^ | U.S. Air Force 1989
Vapor pressure^e^
at 60 °C | 465 mm Hg | ASTM 1989
at 56 °C | 518 mm Hg
at 51 °C | 593 mm Hg
at 47 °C | 698 mm Hg
at 41 °C | 773 mm Hg
Henry’s law constant at 20 °C | 4.8×10^−4^ m^3^/mol^d^ | U.S. Air Force 1989
Autoignition temperature | 280–486 °C | Sax and Lewis 1989; Weiss
Flashpoint | −46 °C | Sax and Lewis 1989
Flammability limits | 1.4–7.4% | Weiss 1986
Conversion factors | No data
Explosive limits | 1.3–6.0% | Sax and Lewis 1989

a Average molecular weight

b Temperature not specified

c Not specified whether data for air or water

d Since data are not available for gasoline, ranges are given indicating different values for the individual components.

e The American Society for Testing and Materials (ASTM) has established guidelines on compositions of gasoline that will permit satisfactory performance under varying conditions. These guidelines define 5 volatility classes that vary by seasonal climatic changes. The values given for vapor pressure at the given temperatures are based on these volatility classes.

Table E-2.a Chemical Identity of Stoddard Solvent^a^

Character | Information | Reference
Chemical Name | Stoddard solvent | ATSDR 1995b
Synonym(s) | Dry cleaning safety solvent, naphtha safety solvent, PD-680, petroleum solvent, spotting naphtha, varnoline, white spirits | ATSDR 1995b; U.S. Air Force 1989
Registered Trade Name(s) | Texsolve S, Varsol 1 | ATSDR 1995b
Identification Numbers:
CAS Registry | 8052-41-3 | ATSDR 1995b
NIOSH RTECS | WJ8925000 | ATSDR 1995b
EPA Hazardous Waste | No data
OHM/TADS | No data
DOT/UN/NA/IMCO shipping | 1268 27 | ATSDR 1995b
HSDB | No data
NCI | No data

a Stoddard solvent is a mixture of C-7 through C-12 hydrocarbons primarily containing 30–50% linear and branched alkanes, 30–40% cycloalkanes, and 10–20% aromatic hydrocarbons.

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute

NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data Systems; RTECS = Registry of Toxic Effects of Chemical Substances

Table E-2.b Possible Formulations of Stoddard Solvent (Percent)

Hydrocarbons | Stoddard solvent^a^ (regular) | Stoddard solvent^a^ (140 flash) | Stoddard solvent^b^ | Stoddard solvent^c^ | Stoddard solvent^d^
Alkanes (paraffins) | 30–50 (48 average) | 60.8 | 34.9 | 41.6 | 47.7
n-Nonane
n-Decane
Methylnonanes
2,6-Dimethyloctane
n-Undecane
Dodecanes
Terdecanes
Others
Cycloalkanes (cycloparaffins) | 30–40 (38 average) | 35.7 | | 39.5 | 37.6
Monocycloparaffins | | 24.5 | 34.9 | 27.9 | 26
Trimethylcyclohexane
tert-Butylcyclohexane
n-Butycyclopentane
n-Butycyclohexane
Other Cycloparaffins
Dicycloparaffins | | 11.2 | 5 | 11.6 | 11.6
Tricycloparaffins | | | 0.4 | 0.00
Acenaphthenes | | | 0.4
Aromatics | 10–20 (14.1 average) | 3.4 | | 18.9
Alkylbenzenes | 14 | 3.03 | 22 | 17.6 | 14.1
Dimethylethylbenzenes
n-Propylbenzene
Ethyltoluenes
1,2,4-Trimethylbenzene
Other aromatics | | | 1.1
Other benzenes | 0.1 | 0.07 | | | 0.1
Indans/Tetralins | <1 | 0.3 | 1.8 | 1.3 | 0.5
Indenes | | | 0.1
Naphthalenes | | | 0.2
Acenaphthalenes | | | 0.3
Tricyclicaromatics | | | 0.1

a Adapted from Air Force (1989)

b Adapted from American Petroleum Institute (1976)

c Adapted from Suntech Group (1978); API 1978

d Adapted from Carpenter et al. (1975); this paper also includes a mass spectral analysis of components by carbon number within a hydrocarbon class, e.g., C_8_ alkanes

Table E-2.c Physical and Chemical Properties of Stoddard Solvent

Property | Information | Reference
Molecular weight | 144 (mean); 135–145 (range) | Air Force 1989b; Carpenter et al. 1975b
Color | Clear, colorless | Sax and Lewis 1989
Physical state | Liquid | Sax and Lewis 1989
Melting point | No data
Boiling point | 154–202 °C | Air Force 1989b
| 160–199 °C | Coast Guard 1985
Density at 20 °C | 0.78 g/mL | NIOSH 1990
Odor | Similar to kerosene | NIOSH 1990
Odor threshold | 0.9 ppm (5.1 mg/m^3^) | Carpenter et al. 1975b
| 2 mg/m^3^ | Hastings et al. 1984
Solubility:
Water | Insoluble | McDermott 1975
Organic solvents | Absolute alcohol, benzene, ether, chloroform, carbon tetrachloride, carbon disulfide | Sax and Lewis 1989
Partition coefficients: | | Air Force 1989b
Log K_ow_ | 3.16–7.06 | Air Force 1989b
Log K_oc_ | 2.85–6.74
Vapor pressure at 25 °C | 4–4.5 mm Hg | McDermott 1975
Henry’s law constant at 20 °C | 4.4×10^0^ atm-m^3^/mol | Air Force 1989b
Autoignition temperature | 232 °C | Sax and Lewis 1989
Flashpoint | 37.8–60.0 °C | Air Force 1989b
| 38–43 °C | Sax and Lewis 1989
Flammability limits in air at 25 °C | 0.9–6.0 | Carpenter et al. 1975b
Conversion factors:
at 25 °C and 760 mm | 1 mg/L = 174.5 ppm | Carpenter et al. 1975b
| 1 ppm = 5.73 mg/m^3^ | Air Force 1989b
Explosive limits | | McDermott 1975
Lower limit | 0.9%
Upper limit | 6%

Table E-3a Chemical Identity, Composition and Chemical Physical Properties of JP-4^a^

Character | Information | Reference
Chemical Name | JP-4 | OHM/TADS 1985
Synonym(s) | Jet Fuel-4 | OHM/TADS 1985
Registered Trade Name(s) | NIL-T-5624-L-Amd. 1; wide cut; JP-4 military (gasoline type) | Air Force 1990c; Dickson and Woodard 1987; Dukek 1978; IARC 1989
Identification Numbers:
CAS Registry | 50815-00-4 | OHM/TADS 1985
NIOSH RTECS | NY9340000 | RTECS 1991
EPA Hazardous Waste | No data
OHM/TADS | 7217071 | OHM/TADS 1985
DOT/UN/NA/IMCO shipping | 1863 | CHRIS 1986
HSDB | No data
NCI | No data

a JP-4 is a mixture of C-4 to C-16 hydrocarbons with an approximate distribution by chemical class of 32% straight alkanes, 31% branched alkanes, 16% cycloalkanes, and 21% aromatic hydrocarbons.

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data Systems; RTECS = Registry of Toxic Effects of Chemical Substances

Table E-3.b Typical Hydrocarbon Composition of JP-4 Jet Fuel

Compound | Weight Percent
Straight Alkanes | 32
Butane | 0.12
Pentane | 1.06
Hexane | 2.21
Heptane | 3.67
Octane | 3.80
Nonane | 2.25
Decane | 2.16
Undecane | 2.32
Dodecane | 2.00
Tridecane | 1.52
Tetradecane | 0.73
Pentadecane | —
Hexadecane | —
Heptadecane | —
Octadecane | —
Isoalkanes | 31
Isobutane | 0.66
2,2-Dimethylbutane | 0.10
2-Methylpentane | 1.28
3-Methylpentane | 0.89
2,2-Dimethylpentane | 0.25
2-Methylhexane | 2.35
3-Methylhexane | 1.97
2,2,3,3-Tetramethylbutane | 0.24
2,5-Dimethylhexane | 0.37
2,4-Dimethylhexane | 0.58
3,3-Dimethylhexane | 0.26
2,2-Dimethylhexane | 0.71
2-Methylheptane | 2.70
4-Methylheptane | 0.92
3-Methylheptane | 3.04
2,5-Dimethylheptane | 0.52
2,4-Dimethylheptane | 0.43
4-Ethylheptane | 0.18
4-Methyloctane | 0.86
2-Methyloctane | 0.88
3-Methyloctane | 0.79
2-Methylundecane | 0.64
2,6-Dimethylundecane | 0.71
2,4,6-Trimethylheptane | —
4-Methyldecane | —
2-Methyldecane | —
2,6-Dimethyldecane | —
2-Methylundecane | —
2,6-Dimethylundecane | —
Cycloalkanes | 16
Methylcyclopentane | 1.16
Cyclohexane | 1.24
trans-1,3-Dimethylcyclopentane | 0.36
cis-1,3-Dimethylcyclopentane | 0.34
cis-1,2-Dimethylcyclopentane | 0.54
Methylcyclohexane | 2.27
Ethylclopentane | 0.26
1,2,4-Trimethylcyclopentane | 0.25
1,2,3-Trimethylcyclopentane | 0.25
cis-1,3-Dimethylcyclohexane | 0.42
1-Methyl-3-ethylcyclohexane | 0.17
1-Methyl-2-ethylcyclohexane | 0.39
Dimethylcyclohexane | 0.43
1,3,5-Trimethylcyclohexane | 0.99
1,1,3-Trimethylcyclohexane | 0.48
1-Methyl-4-ethylcyclohexane | 0.48
n-Butylcyclohexane | 0.70
Propylcyclohexane | —
Hexylcyclohexane | —
Heptylcyclohexane | —
Aromatic Hydrocarbons | 21
Benzene | 0.50
Toluene | 1.33
Ethylbenzene | 0.37
m-Xylene | 0.96
p-Xylene | 0.35
o-Xylene | 1.01
Isopropylbenzene | 0.30
n-Propylbenzene | 0.71
1-Methyl-3-ethylbenzene | 0.49
1-Methyl-4-ethylbenzene | 0.43
1,3,5-Trimethylbenzene | 0.42
1-Methyl-2-ethylbenzene | 0.23
1,2,4-Trimethylbenzene | 1.01
1,3-Diethylbenzene | 0.46
1,4-Diethylbenzene | —
1-Methyl-4-propylbenzene | 0.40
1,3-Dimethyl-5-ethylbenzene | 0.61
1-Methyl-2-isopropylbenzene | 0.29
1,4-Dimethyl-2-ethylbenzene | 0.70
1,2-Dimethyl-4-ethylbenzene | 0.77
1,2,3,4-Tetramethylbenzene | 0.75
1-Ethylpropylbenzene | —
1,2,4-Triethylbenzene | —
1,3,5-Triethylbenzene | —
Phenylcyclohexane | —
1-tert-Butyl-3,4,5-trimethylbenzene | —
n-Heptylbenzene | —
Naphthalene | 0.50
2-Methylnaphthalene | 0.56
1-Methylnaphthalene | 0.78
2,6-Dimethylnaphthalene | 0.25
Biphenyl | —
1-Ethylnaphthalene | —
2,3-Dimethylnaphthalene | —
n-Octylbenzene | —

Table E-3.c Physical and Chemical Properties of JP-4^a^

Property | Information | Reference
Molecular weight | Not applicable^b^
Color | Colorless to straw colored | CHRIS 1986; Martel 1992
Physical state | Liquid | CHRIS 1986
Melting point | −46 °C | OHM/TADS 1985
| −40–72 °C | ITC 1985
Boiling point (1 atm) | 50–270 °C | Air Force 1989b
| 90–300 °C | ITC 1985
| 45–280 °C | Dickson and Woodward 1987
Density at 15 °C | 751–802 kg/m^3^ (specification)
Odor | Like gasoline and/or kerosene
Odor threshold:
Water | No data
Air | 1 ppm | CHRIS 1986
Solubility:
Water at 20 °C | 57 mg/L | CRC 1984
Organic solvents | Since many of the components are organic solvents, the fuel is generally miscible with organic solvents | ITC 1985
Partition coefficients:
Log K_ow_ | Major components range from 3 to 4.5 | ITC 1985
| No data
Log K_oc_
Vapor pressure at 20 °C | 91 mm Hg | Air Force 1989b
Henry’s law constant | 1.00×10^−4^–1.00×10^1^ atm-m^3^/mol | Air Force 1989b
Autoignition temperature | 246 °Cd | CRC 1984
Flashpoint | −23–1 °C | NFPA 1986
Flammability limits | 1.3% lower; 8.0 upper | NFPA 1986
Explosive limits | No data

a JP4, or jet propellant-4, is a mixed compound composed primarily of hydrocarbons (i.e., alkanes, cycloalkanes, alky-benzenes, indan/tetralins, and Naphthalenes).

b Jet fuels are blends prepared to meet certain gross property specifications. Most characteristic data only reflect gross properties covered in the specifications. Proportions and values vary with the type of crude oil from which the final fuel is derived and the refining process used.

Table E-4.a Chemical Identity of Fuel Oils

Character | Information
Chemical Name | Fuel oil No. 1^a^ | Fuel Oil No. 2^b^ | Fuel oil No. 6^c^
Synonym(s) | Kerosene, coal oil kerosine, range oil, straight run kerosene, distillate fuel oils light, furnace oil no. 1, Deobase^®^, JP-5, JP-1, range oil | API no. 2 fuel oil, gas oil, home heating oil no. 2, number 2 burner oil, diesel fuel, furnace oil no. 2 | No. 6 fuel oil, Bunker C
Registered Trade Name(s) | Deobase^®^
Identification Numbers:
CAS Registry | 8008-20-6 | 68476-30-2 | 68553-00-4
NIOSH RTECS | OA5500000 | HZ1800000 | LS8940000
EPA Hazardous Waste | No data | No data | No data
OHM/TADS | 7217063 | No data | No data
DOT/UN/NA/IMCO shipping | UN 1223, IMO 3.3 | No data | No data
DOT/UN/NA/IMCO shipping | 632 | No data | No data
HSDB | No data | C54795 | No data
NCI

a Fuel oil #1 is a mixture of C-9 through C-16 hydrocarbons primarily containing approximately 64% aliphatic hydrocarbons, 1–2% olefinic hydrocarbons, and 35% aromatic hydrocarbons.

b Fuel oil #2 is a mixture of C-11 to C-20 hydrocarbons.

c Fuel oil #6 is 25% aromatics, 15% paraffins, 45% naphthenes, and 15% non-hydrocarbon compounds

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection

Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute

NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data Systems; RTECS = Registry of Toxic Effects of Chemical Substances

Source: ATSDR Toxicological Profile for Fuel Oils, 1995.

Table E-4b Analysis of Fuel Oils^a^

| Volume %
Hydrocarbon type | Fuel oil no. 1 | Fuel oil no. 2 | Fuel Oil no. 6
Paraffins (n- and iso-) | 52.4 | 41.3 | 5.9
Monocycloparaffins | 21.3 | 22.1 | 3.9
Bicycloparaffins | 5.1 | 9.6 | 3.4
Tricycloparaffins | 0.8 | 2.3 | 2.9
Other cycloparaffins | - | - | 5.0
Total saturated hydrocarbons | 79.7 | 75.3 | 21.1
Olefins | No data | No data | No data
Alkylbenzenes | 13.5 | 5.9 | 1.9
Indans/tetralins | 3.3 | 4.1 | 2.1
Dinaphthenobenzenes/indenes | 0.9 | 1.8 | 2.6
Naphthalenes | 2.8 | 8.2 | 2.6
Biphenyls/acenaphthenes | 0.4 | 2.6 | 3.1
Flurenes/acenphthylenes | No data | 1.4 | 7.0
Phenanthrenes | No data | 0.7 | 11.6
Other aromatic hydrocarbons | No data | No data | 57.8
Total aromatic hydrocarbons | 23.6 | 24.7 | 78.9

a Derived from IARC 1989; provided by the American Petroleum Institute

Table E-4c Physical and Chemical Properties of Fuel Oils

Property | Fuel oil no. 1 | Fuel oil no. 2 | Fuel oil no. 6
Molecular weight | No data | No data | No data
Color | Pale Yellow^b^; Colorless to brown^c,d^ | Colorless to brown^c^ | Colorless to brown
Physical state | Liquid^c^ | Liquid^c^ | Liquid
Melting point | −45.6 °C | −29 °C | No data
Boiling point | 175–325 °C^b^; 200–260 °C^d^ | 160–360 °C^f^; 282–338 °C^d^ | 151–588 °C
Density
at 15°C | 0.810–0.9360 g/mL^c^ | No data | No data
at 20 °C | 0.80 g/mL^e,f^ | 0.8700–0.9500 ^c^ | No data
Odor | Kerosene-like^c^ | Kerosene-like^c^ | Kerosene-like
Odor threshold (ppm) | 0.082^f^; 1^d^ | No data | No data
Solubility:
Water at 20 °C | ≈5 mg/L^c^ | ≈5 mg/L^c^ | ≈5 mg/L
Organic solvents | Miscible with other petroleum solvents^b^ | No data | No data
Partition coefficients:
Log K_ow_ | 3.3–7.06^c^ | 3.3–7.06^c^ | 3.3–7.06
Log K_oc_ | 3.0–6.7^c^ | 3.0–6.7^c^ | 3.0–6.7
Vapor pressure at 21 °C | 2.12–26.4 mm Hg^c^ | 2.12–26.4 mm Hg^c^ | No data
Henry’s law constant at 20 °C - atm-m^3^/mol | 5.9×10^−5^–7.4^c^ | 5.9×10^−5^–7.4^c^ | No data
Autoignition temperature | 229 °C^d^ | 257 °C^d^ | No data
Flashpoint (close cup) | 38 °C^c,d^ | 58 °C^d^ | No data
Flammability limits (% volume in air) | 0.7–5%^d^ | 0.6–7.5%^d^ | No data
Conversion factors | No data | No data | No data
Explosive limits | 0.7–5%^b^ | No data | No data

a Values listed are specifications required or general characteristics of each class of fuel oils

b HSDB 1991

c Air Force 1989

d Coast Guard 1985

e IARC 1989

Source: ATSDR toxicological profile for Fuel Oils

Table E-5.a Chemical Identity of Mineral-Based Crankcase Oil

Character | Information | Reference
Chemical Name | Mineral-based crankcase oil | ATSDR 1997c
Synonym (s) | API 79-7; API service classification SAE 30 automotive motor oil; monograde automotive engine oil; multigrade automotive engine oil; marine engine oil; base engine oil; monograde diesel oil; railway diesel oil; marine diesel oil | ATSDR 1997c
Registered Trade Name(s) | Not applicable
Chemical Formula | Not applicable
Chemical Structure | Not applicable
Identification Numbers:
CAS Registry | 8002-05-9 | IARC 1984
NIOSH RTECS | No data
EPA Hazardous Waste | No data
OHM/TADS | No data
DOT/UN/NA/IMCO shipping | No data
HSDB | No data
NCI | No data

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute

NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data Systems; RTECS = Registry of Toxic Effects of Chemical Substances

Table E-5.b Concentration of Components in Used Mineral-Based Crankcase Oil^a^

Component | Median concentration (ppm)
Arsenic | 5
Barium | 48
Cadmium | 3
Chromium | 6.5
Lead | 240
Zinc | 480
Dichlorodifluoromethane | 20
Trichlorotrifluoroethane | 160
1,1,1-Trichloroethane | 200
Trichloroethylene | 100
Tetrachloroethylene | 106
Benzene | 20
Toluene | 380
Xylene | 550
Benz(a)anthracene | 12
Benzo(a)pyrene | 10
Naphthalene | 330
PCBs | 5

a Environmental contamination from mineral-based crankcase oil is more likely to be from used crankcase oil than for the fresh products. Used oil is significantly contaminated with heavy metals and polycyclic aromatic hydrocarbons that are insignificant in the unused products. TPH results do not yield values for these contaminants, but the table is provided for informational purposes.

Source: ABB-Environmental Service, Inc. 1990

Table E-5.c Physical and Chemical Properties of Mineral-Based Crankcase Oils

Property | Information | References
Molecular weight | No data
Color | Yellow brown | DOE 1989
Physical state | Liquid, oily | DOE 1989
Melting point | −34.4 °C | DOE 1989
Boiling point | 360 °C | DOE 1989
Density at 20 °C | Not applicable
Odor | Lube oil odor | DOE 1989
Odor threshold (ppm) | No data
Solubility
Water at 20 °C | Insoluble | DOE 1989
Organic solvents | No data
Partition coefficients:
Log K_ow_ | No data
Log K_oc_ | No data
Vapor pressure at 21 °C | No data
Henry’s law constant at 20 °C - atm-m^3^/mol | No data
Autoignition temperature | ≥135 °C | DOE 1989
Flashpoint (close cup) | ≥163 °C | DOE 1989
Flammability limits (% volume in air) | No data
Conversion factors | No data
Explosive limits | No data

Source: ATSDR. 1997. Toxicological profile for mineral-based crankcase oil. Agency for Toxic Substances and Disease Registry. Atlanta, GA.

Table E-6a Chemical Identity of Mineral Oil^a^

Character | Information | Reference
Chemical Name | Mineral Oil | RTECS 1995
Synonym(s) | Paraffin oils, Heavy mineral oil, Light mineral oil, Liquid paraffin, Aliphatic petroleum hydrocarbons, Liquid Vaseline, Paraffins, Paroleine, Liquid Petrolatum, White Mineral Oil, White Oils | RTECS 1995; ATSDR 1997b
Registered Trade Name(s) | Nujol, Thermia C, ADEPSINE OIL, ALBOLINE, Balneol, BAYOL F, Bayol 55, Blandlube, Crystosol, Drakeol, FLEXON 845, Fonoline, GLYMOL, Crystosol, IRGAWAX 361, KAYDOL, Kondremul, MagieSol 44, Molol, Neo-Cultol, Parol, Peneteck, Penreco, Perfecta, Petrogalar, PRIMOL D, Primol 355, Protopet, SAXOL, SHELLFLEX 371N, SUNPAR 150, Tech Pet F, ULTROL 7, UVASOL
Identification Numbers:
CAS Registry | 8020-83-5; 8012-95-1 | RTECS 1995
NIOSH RTECS | LX3300000 | RTECS 1995
EPA Hazardous Waste | No data
OHM/TADS | 7217073 | OHM/TADS 1991
DOT/UN/NA/IMCO shipping | UN1203, UN1257 | RTECS 1995
HSDB | No data
NCI | No data

a Mineral oil refers to classes of petroleum hydrocarbons whose origin is petroleum distillation streams. Light paraffinic (naphthenic) distillate contains C_15_–C_30_ hydrocarbons; heavy paraffinic (naphthenic) distillate contains C_20_–C_50_ hydrocarbons; white mineral oil contains C_15_–C_50 _hydrocarbons, and petrolatum and most residual oils contains >C_25_ hydrocarbons. Source: IARC 1984.

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data Systems; RTECS = Registry of Toxic Effects of Chemical Substances

Table E-6.b Physical and Chemical Properties of Mineral Oil^a^

Property | Information | Reference
Molecular weight | No data
Color | Clear | HSDB 1998
Physical state | Liquid | HSDB 1998
Melting point | No data
Boiling point | 360°C | HSDB 1998
Density at 20/4 °C | 0.875–0.905 | HSDB 1998
Odor | Like burned lubricating oil | HSDB 1998
Odor threshold: | No data
Water
Air
Solubility:
Water at 25 °C | Insoluble | HSDB 1998
Organic solvents | Soluble | HSDB 1998
Partition coefficients:
Log K_ow_ | No data
Log K_oc_ | No data
Vapor pressure at 20/30 °C | No data
Henry’s law constant at 24.8 °C | No data
Autoignition temperature | 500–700°F | HSDB 1998
Flashpoint | 135°C (closed cup) | HSDB 1998
| 193°C (open cup) | HSDB 1998
Flammability limits in air | No data
Conversion factors:
ppm (v/v) to mg/m^3^ in air at 25 °C | 1 ppm (v/v) =3.96 mg/m^3^
mg/m^3^ to ppm (v/v) in air at 25 °C | 1 mg/m^3^ =0.25 ppm (v/v)
Explosive limits | No data

a Mineral oil refers to classes of petroleum hydrocarbons whose origin is petroleum distillation streams. Light paraffinic (naphthenic) distillate contains C_15_–C_30_ hydrocarbons; heavy paraffinic (naphthenic) distillate contains C_20_–C_50_ hydrocarbons; white mineral oil contains C_50_ hydrocarbons, and; petrolatum and most residual oils contains >C_25_ hydrocarbons. Source: IARC 1984.

Source: HSDB. 1998. Hazardous Substances Database. Environmental Protection Agency, available through National Library of Medicine, MEDLARS, Washington, DC.