# APPENDIX D PETROLEUM PRODUCT COMPOSITION

Petroleum products can be made up of hundreds of individual petroleum hydrocarbons. TPH is a value that represents the amount of petroleum hydrocarbons in a given sample, as previously presented in Section 2.1. There are far more than 250 individual chemicals that are known as petroleum hydrocarbons and there is an inherent complexity involved in chemically and physically describing and categorizing these components.

This Appendix contains a list of the more prominent individual chemicals that are likely to be associated with TPH. Table D-1 sorts the petroleum hydrocarbons into groups based upon basic chemical structure, An “ATSDR Fraction” column identifies which one of six particular fractions individual chemicals have been assigned to for health effects purposes, as described in Section 6.1.3 and shown below.

- Aliphl = Aliphatics EC_5_-EC_8_
- Aliph2 = Aliphatics EC_>8_-EC_16_
- Aliph3 = Aliphatics EC_>16_-EC_35_
- Aroml = Aromatics EC_5_-EC_9_
- Arom2 = Aromatics EC_>9_-EC_16_
- Arom3 = Aromatics EC_>16_-EC_35_

Table D-1 Petroleum Product Composition

Compound | Carbon Number | EC^a^ | ATSDR Fraction^b^ | Weight Percent | Fuel Type | Reference
Straight Chain Alkanes
Propane | 3 | 3 | | 0.01–0.14 | Gasoline | LUFT 1988
n-Butane | 4 | 4 | | 3.93–4.70 | Gasoline | LUFT 1988
| | | | 0.12 | JP-4 | API 1993
n-Pentane | 5 | 5 | Aliph1 | 5.75–10.92 | Gasoline | LUFT 1988
| | | | 1.06 | JP-4 | API 1993
n-Hexane | 6 | 6 | Aliph1 | 0.24–3.50 | Gasoline | LUFT 1988
| | | | 0.7–1.8 | Crude Oil | API 1993
| | | | 2.21 | JP-4 | API 1993
n-Heptane | 7 | 7 | Aliph1 | 0.31–1.96 | Gasoline | LUFT 1988
| | | | 0.8–2.3 | Crude Oil | API 1993
| | | | 3.67 | JP-4 | API 1993
| | | | 0.03 | JP-8 | API 1993
| | | | 0.1 | Kerosene | API 1993
n-Octane | 8 | 8 | Aliph1 | 0.36–1.43 | Gasoline | LUFT 1988
| | | | 0.9–1.9 | Crude Oil | API 1993
| | | | 3.8 | JP-4 | API 1993
| | | | 0.12 | JP-5 | API 1993
| | | | 0.9 | JP-8 | API 1993
| | | | 0.2–0.3 | Kerosene | API 1993
| | | | 0.1 | Diesel | BP 1996
| | | | 0.1 | Fuel Oil #2 | BP 1996
n-Nonane | 9 | 9 | Aliph2 | 0.07–0.83 | Gasoline | LUFT 1988
| | | | 0.6–1.9 | Crude Oil | API 1993
| | | | 2.25 | JP-4 | API 1993
| | | | 0.38 | JP-5 | API 1993
| | | | 0.31 | JP-8 | API 1993
| | | | 0.4–0.8 | Kerosene | API 1993
| | | | 0.19–0.49 | Diesel | BP 1996
| | | | 0.20–0.30 | Fuel Oil #2 | BP 1996
n-Decane | 10 | 10 | Aliph2 | 0.04–0.50 | Gasoline | LUFT 1988
| | | | 1.8 | Crude Oil | API 1993
| | | | 2.16 | JP-4 | API 1993
| | | | 1.79 | JP-5 | API 1993
| | | | 1.31 | JP-8 | API 1993
| | | | 1.5–1.7 | Kerosene | API 1993
| | | | 0.28–1.2 | Diesel | BP 1996
| | | | 0.5 | Fuel Oil #2 | BP 1996
n-Undecane | 11 | 11 | Aliph2 | 0.05–0.22 | Gasoline | LUFT 1988
| | | | 1.7 | Crude Oil | API 1993
| | | | 2.32 | JP-4 | API 1993
| | | | 3.95 | JP-5 | API 1993
| | | | 4.13 | JP-8 | API 1993
| | | | 3.5–6.1 | Kerosene | API 1993
| | | | 0.57–2.3 | Diesel | BP 1996
| | | | 0.80–0.90 | Fuel Oil #2 | BP 1996
n-Dodecane | 12 | 12 | Aliph2 | 0.04–0.09 | Gasoline | LUFT 1988
| | | | 1.7 | Crude Oil | API 1993
| | | | 2 | JP-4 | API 1993
| | | | 3.94 | JP-5 | API 1993
| | | | 4.72 | JP-8 | API 1993
| | | | 2.8–5.7 | Kerosene | API 1993
| | | | 1.0–2.5 | Diesel | BP 1996
| | | | 0.84–1.20 | Fuel Oil #2 | BP 1996
n-Tridecane | 13 | 13 | Aliph2 | 1.52 | JP-4 | API 1993
| | | | 3.45 | JP-5 | API 1993
| | | | 4.43 | JP-8 | API 1993
| | | | 3.1–5.2 | Kerosene | API 1993
| | | | 1.5–2.8 | Diesel | BP 1996
| | | | 0.96–2.00 | Fuel Oil #2 | BP 1996
n-Tetradecane | 14 | 14 | Aliph2 | 0.73 | JP-4 | API 1993
| | | | 2.72 | JP-5 | API 1993
| | | | 2.99 | JP-8 | API 1993
| | | | 2.3–4.7 | Kerosene | API 1993
| | | | 0.61–2.7 | Diesel | BP 1996
| | | | 1.03–2.50 | Fuel Oil #2 | BP 1996
n-Pentadecane | 15 | 15 | Aliph2 | 1.67 | JP-5 | API 1993
| | | | 1.61 | JP-8 | API 1993
| | | | 0.6–2.3 | Kerosene | API 1993
| | | | 1.9–3.1 | Diesel | BP 1996
| | | | 1.13–3.20 | Fuel Oil #2 | BP 1996
n-Hexadecane | 16 | 16 | Aliph2 | 1.07 | JP-5 | API 1993
| | | | 0.45 | JP-8 | API 1993
| | | | 0.1–0.7 | Kerosene | API 1993
| | | | 1.5–2.8 | Diesel | BP 1996
| | | | 1.05–3.30 | Fuel Oil #2 | BP 1996
n-Heptadecane | 17 | 17 | Aliph3 | 0.12 | JP-5 | API 1993
| | | | 0.08 | JP-8 | API 1993
| | | | 0.4 | Kerosene | API 1993
| | | | 1.4–2.9 | Diesel | BP 1996
| | | | 0.65–3.60 | Fuel Oil #2 | BP 1996
n-Octadecane | 18 | 18 | Aliph3 | 0.02 | JP-8 | API 1993
| | | | 0.3 | Kerosene | API 1993
| | | | 1.2–2.0 | Diesel | BP 1996
| | | | 0.55–2.50 | Fuel Oil #2 | BP 1996
n-Nonadecane | 19 | 19 | Aliph3 | 0.2 | Kerosene | API 1993
| | | | 0.7–1.5 | Diesel | BP 1996
| | | | 0.33–1.30 | Fuel Oil #2 | BP 1996
n-Eicosane | 20 | 20 | Aliph3 | 0.1 | Kerosene | API 1993
| | | | 0.4–1.0 | Diesel | BP 1996
| | | | 0.18–0.60 | Fuel Oil #2 | BP 1996
n-Heneicosane | 21 | 21 | Aliph3 | 0.1 | Kerosene | API 1993
| | | | 0.26–0.83 | Diesel | BP 1996
| | | | 0.09–0.40 | Fuel Oil #2 | BP 1996
n-Docosane | 22 | 22 | Aliph3 | 0.14–0.44 | Diesel | BP 1996
| | | | 0.1 | Fuel Oil #2 | BP 1996
n-Tetracosane | 24 | 24 | Aliph3 | 0.35 | Diesel | BP 1996
n-Hexacosane | 26 | 26 | Aliph3
Branched Chain Alkanes
Isobutane | 4 | 3.67 | | 0.12–0.37 | Gasoline | LUFT 1988
| | | | 0.66 | JP-4 | API 1993
2,2-Dlmethylbutane | 6 | 5.37 | Aliph1 | 0.17–0.84 | Gasoline | LUFT 1988
| | | | 0.04 | Crude Oil | API 1993
| | | | 0.1 | JP-4 | API 1993
2,3-Dimethylbutane | 6 | 5.68 | Aliph1 | 0.59–1.55 | Gasoline | LUFT 1988
| | | | 0.04–0.14 | Crude Oil | API 1993
2,2,3-Trimethylbutane | 7 | 6.36 | Aliph1 | 0.01–0.04 | Gasoline | LUFT 1988
2,2,3,3-Tetramethylbutane | 8 | 7.3 | Aliph1 | 0.24 | JP-4 | API 1993
Neopentane | 5 | 4.32 | | 0.02–0.05 | Gasoline | LUFT 1988
Isopentane | 5 | 4.75 | | 6.07–10.17 | Gasoline | LUFT 1988
2-Methylpentane | 6 | 5.72 | Aliph1 | 2.91–3.85 | Gasoline | LUFT 1988
| | | | 0.3–0.4 | Crude Oil | API 1993
| | | | 1.28 | JP-4 | API 1993
3-Methylpentane | 6 | 5.85 | Aliph1 | 2.4 (vol) | Gasoline | LUFT 1988
| | | | 0.3–0.4 | Crude Oil | API 1993
| | | | 0.89 | JP-4 | API 1993
3-Ethylpentane | 7 | | Aliph1 | 0.05 | Crude Oil | API 1993
2,2-Dimethylpentane | 7 | 6.25 | Aliph1 | 0.25 | JP-4 | API 1993
2,4-Dimethylpentane | 7 | 6.31 | Aliph1 | 0.23–1.71 | Gasoline | LUFT 1988
| | | | 0.05 | Crude Oil | API 1993
2,3-Dimethylpentane | 7 | 6.69 | Aliph1 | 0.32–4.17 | Gasoline | LUFT 1988
| | | | 0.1–0.6 | Crude Oil | API 1993
3,3-Dimethylpentane | 7 | 6.55 | Aliph1 | 0.02–0.03 | Gasoline | LUFT 1988
2,2,3-Trimethylpentane | 8 | 7.37 | Aliph1 | 0.09–0.23 | Gasoline | LUFT 1988
2,2,4-Trimethylpentane | 8 | 6.89 | Aliph1 | 0.32–4.58 | Gasoline | LUFT 1988
| | | | 0.004 | Crude Oil | API 1993
2,3,3-Trimethylpentane | 8 | 7.58 | Aliph1 | 0.05–2.28 | Gasoline | LUFT 1988
| | | | 0.006 | Crude Oil | API 1993
2,3,4-Trimethylpentane | 8 | 7.55 | Aliph1 | 0.11–2.80 | Gasoline | LUFT 1988
| | | | 0.005 | Crude Oil | API 1993
2-Methyl-3-ethylpentane | 8 | 7.66 | Aliph1 | 0.04 | Crude Oil | API 1993
2,4-Dimethyl-3-ethylpentane | 9 | | Aliph2 | 0.03–0.07 | Gasoline | LUFT 1988
2-Methylhexane | 7 | 6 | Aliph1 | 68 0.36–1.48 | Gasoline | LUFT 1988
| | | | 0.7 | Crude Oil | API 1993
| | | | 2.35 | JP-4 | API 1993
3-Methylhexane | 7 | 6.76 | Aliph1 | 0.30–1.77 | Gasoline | LUFT 1988
| | | | 0.19–0.5 | Crude Oil | API 1993
| | | | 1.97 | JP-4 | API 1993
2,2-Dimethylhexane | 8 | 7.25 | Aliph1 | 0.01–0.1 | Crude Oil | API 1993
| | | | 0.71 | JP-4 | API 1993
2,3-Dimethylhexane | 8 | 7.65 | Aliph1 | 0.06–0.16 | Crude Oil | API 1993
2,4-Dimethylhexane | 8 | 7.38 | Aliph1 | 0.34–0.82 | Gasoline | LUFT 1988
| | | | 0.06 | Crude Oil | API 1993
| | | | 0.58 | JP-4 | API 1993
2,5-Dimethylhexane | 8 | 7.36 | Aliph1 | 0.24–0.52 | Gasoline | LUFT 1988
| | | | 0.06 | Crude Oil | API 1993
| | | | 0.37 | JP-4 | API 1993
3,3-Dimethylhexane | 8 | 7.45 | Aliph1 | 0.03 | Crude Oil | API 1993
| | | | 0.26 | JP-4 | API 1993
3,4-Dimethylhexane | 8 | 7.74 | Aliph1 | 0.16–0.37 | Gasoline | LUFT 1988
3-Ethylhexane | 8 | 7.79 | Aliph1 | 0.01 | Gasoline | LUFT 1988
2-Methyl-3-ethylhexane | 9 | | | 0.04–0.13 | Gasoline | LUFT 1988
2,2,4-Trimethylhexane | 9 | 7.93 | Aliph1 | 0.11–0.18 | Gasoline | LUFT 1988
2,2,5-Trimethylhexane | 9 | 7.87 | Aliph1 | 0.17–5.89 | Gasoline | LUFT 1988
2,3,3-Trimethylhexane | 9 | | | 0.05–0.12 | Gasoline | LUFT 1988
2,3,5-Trimethylhexane | 9 | 8.24 | Aliph2 | 0.05–1.09 | Gasoline | LUFT 1988
2,4,4-Trimethylhexane | 9 | 8.07 | | 0.02–0.16 | Gasoline | LUFT 1988
2-Methylheptane | 8 | 7.71 | Aliph1 | 0.48–1.05 | Gasoline | LUFT 1988
| | | | 2.7 | JP-4 | API 1993
3-Methylheptane | 8 | 7.78 | Aliph1 | 0.63–1.54 | Gasoline | LUFT 1988
| | | | 3.04 | JP-4 | API 1993
4-Methylheptane | 8 | 7.72 | Aliph1 | 0.22–0.52 | Gasoline | LUFT 1988
| | | | 0.92 | JP-4 | API 1993
2,2-Dimethylheptane | 9 | 8.28 | Aliph2 | 0.01–0.08 | Gasoline | LUFT 1988
2,3-Dimethylheptane | 9 | 8.64 | Aliph2 | 0.13–0.51 | Gasoline | LUFT 1988
| | | | 0.05 | Crude Oil | API 1993
2,4-Dimethylheptane | 9 | 8.34 | Aliph2 | 0.43 | JP-4 | API 1993
2,5-Dimethylheptane | 9 | 8.47 | Aliph2 | 0.52 | JP-4 | API 1993
2,6-Dimethylheptane | 9 | 8.47 | Aliph2 | 0.07–0.23 | Gasoline | LUFT 1988
| | | | 0.05 –0.25 | Crude Oil | API 1993
3,3-Dimethylheptane | 9 | 8.42 | | 0.01–0.08 | Gasoline | LUFT 1988
3,4-Dimethylheptane | 9 | 8.62 | Aliph2 | 0.07–0.33 | Gasoline | LUFT 1988
2,2,4-Trimethylheptane | 10 | | Aliph2 | 0.12–1.70 | Gasoline | LUFT 1988
2,4,6-Trimethylheptane | 10 | | Aliph2 | 0.07 | JP-5 | API 1993
3,3,5-Trimethylheptane | 10 | | Aliph2 | 0.02–0.06 | Gasoline | LUFT 1988
3-Ethylheptane | 9 | 8.77 | Aliph2 | 0.02–0.16 | Gasoline | LUFT 1988
4-Ethylheptane | 9 | 8.69 | Aliph2 | 0.18 | JP-4 | API 1993
2-Methyloctane | 9 | | Aliph2 | 0.14–0.62 | Gasoline | LUFT 1988
| | | | 0.4 | Crude Oil | API 1993
| | | | 0.88 | JP-4 | API 1993
3-Methyloctane | 9 | 8.78 | Aliph2 | 0.34–0.85 | Gasoline | LUFT 1988
| | | | 0.1–0.4 | Crude Oil | API 1993
| | | | 0.79 | JP-4 | API 1993
| | | | 0.07 | JP-5 | API 1993
| | | | 0.04 | JP-8 | API 1993
4-Methyloctane | 9 | 8.71 | Aliph2 | 0.11–0.55 | Gasoline | LUFT 1988
| | | | 0.1 | Crude Oil | API 1993
| | | | 0.86 | JP-4 | API 1993
2,6-Dimethyloctane | 10 | 9.32 | Aliph2 | 0.06–0.12 | Gasoline | LUFT 1988
2-Methylnonane | 10 | 9.72 | Aliph2 | 0.06–0.41 | Gasoline | LUFT 1988
3-Methylnonane | 10 | 9.78 | Aliph2 | 0.06–0.32 | Gasoline | LUFT 1988
4-Methylnonane | 10 | | Aliph2 | 0.04–0.26 | Gasoline | LUFT 1988
4-Methyldecane | 11 | | Aliph2 | 0.78 | JP-5 | API 1993
2-Methyldecane | 11 | | Aliph2 | 0.61 | JP-5 | API 1993
| | | | 0.41 | JP-8 | API 1993
2,6-Dimethyldecane | 12 | | Aliph2 | 0.72 | JP-5 | API 1993
| | | | 0.66 | JP-8 | API 1993
2-Methylundecane | 12 | | Aliph2 | 0.64 | JP-4 | API 1993
| | | | 1.39 | JP-5 | API 1993
| | | | 1.16 | JP-8 | API 1993
3-Methylundecane | 12 | | Aliph2 | 0.09–0.28 | Diesel | BP 1996
2-Methyldodecane | 13 | | Aliph2 | 0.15–0.52 | Diesel | BP 1996
2,6-Dimethylundecane | 13 | | Aliph2 | 0.71 | JP-4 | API 1993
| | | | 2 | JP-5 | API 1993
| | | | 2.06 | JP-8 | API 1993
3-Methyltridecane | 14 | | Aliph2 | 0.13–0.30 | Diesel | BP 1996
2-Methyltetradecane | 15 | | Aliph2 | 0.34–0.63 | Diesel | BP 1996
Cycloalkanes
Cyclopentane | 5 | 5.66 | Aliph1 | 0.19–0.58 | Gasoline | LUFT 1988
| | | | 0.05 | Crude Oil | API 1993
Methylcyclopentane | 6 | 6.27 | Aliph1 | not quantified | Gasoline | LUFT 1988
| | | | 0.3–0.9 | Crude Oil | API 1993
| | | | 1.16 | JP-4 | API 1993
1-Methyl-cis-2-ethylcyclopentane | 8 | | Aliph1 | 0.06–0.11 | Gasoline | LUFT 1988
1-Methyl-trans-3-ethylcyclopentane | 8 | | Aliph1 | 0.06–0.12 | Gasoline | LUFT 1988
1,1-Dimethylcyclopentane | 7 | 6.72 | Aliph1 | 0.06–0.2 | Crude Oil | API 1993
1-cis-2-Dimethylcyclo-pentane | 7 | 7.21 | Aliph1 | 0.07–0.13 | Gasoline | LUFT 1988
| | | | 0.54 | JP-4 | API 1993
1-Trans-2-dimethylcyclo-pentane | 7 | 6.87 | Aliph1 | 0.06–0.20 | Gasoline | LUFT 1988
| | | | 0.15-.5 | Crude Oil | API 1993
1-cis-3-Dimethylcyclopentane | 7 | 6.82 | Aliph1 | 0.2 | Crude Oil | API 1993
| | | | 0.34 | JP-4 | API 1993
1-Trans-3-dimethylcyclopentane | 7 | 6.85 | Aliph1 | 0.2–0.9 | Crude Oil | API 1993
| | | | 0.36J | P-4 | API 1993
1,1,2-Trimethylcyclopentane | 8 | 7.67 | Aliph1 | 0.06–0.1 | Gasoline | LUFT 1988
| | | | 0.06 | Crude Oil | API 1993
1,1,3-Trimethylcyclopentane | 8 | 7.25 | Aliph1 | 0.3 | Crude Oil | API 1993
1-Trans-2-cis-3-trimethylcyclopentane | 8 | 7.51 | Aliph1 | 0.01–0.25 | Gasoline | LUFT 1988
| | | | 0.3–0.4 | Crude Oil | API 1993
1-Trans-2-cis-4-trimethylcyclo-pentane | 8 | | | 0.03–0.16 | Gasoline | LUFT 1988
| | | | 0.2 | Crude Oil | API 1993
1-Trans-2-trans-4-trimethylcyclopentane | 8 | 7.19 | Aliph1
Ethylcyclopentane | 7 | 7.34 | Aliph1 | 0.14–0.21 | Gasoline | LUFT 1988
| | | | 0.26 | JP-4 | API 1993
n-Propylcyclopentane | 8 | 7.1 | Aliph1 | 0.01–0.06 | Gasoline | LUFT 1988
Isopropylcyclopentane | 8 | | Aliph1 | 0.01–0.02 | Gasoline | LUFT 1988
1-cis-3-Dimethylcyclohexane | 8 | 7.75 | Aliph1 | 0.42 | JP-4 | API 1993
1-Trans-2-dimethylcyclohexane | 8 | 7.94 | Aliph1 | 0.3 | Crude Oil | API 1993
1-Trans-3-dimethylcyclohexane | 8 | 7.99 | Aliph1 | 0.05–0.12 | Gasoline | LUFT 1988
1,4-Dimethylcyclohexane | 8
Ethylcyclohexane | 8 | 8.38 | Aliph2 | 0.17–0.42 | Gasoline | LUFT 1988
| | | | 0.2 | Crude Oil | API 1993
Cyclohexane | 6 | 6.59 | Aliph1 | 0.7 | Crude Oil | API 1993
| | | | 0.08 | Gasoline | API 1993
| | | | 1.24 | JP-4 | API 1993
Methylcyclohexane | 7 | 7.22 | Aliph1 | 2.27 | JP-4 | API 1993
1-Methyl-2-ethylcyclohexane | 9 | | Aliph2 | 0.39 | JP-4 | API 1993
1-Methyl-3-ethylcyclohexane | 9 | | Aliph2 | 0.17 | JP-4 | API 1993
1-Methyl-4-ethylcyclohexane | 9 | | Aliph2 | 0.48 | JP-5 | API 1993
| | | | 0.1 | JP-8 | API 1993
1,3,5-Trimethylcyclohexane | 9 | | Aliph2 | 0.99 | JP-4 | API 1993
| | | | 0.09 | JP-5 | API 1993
| | | | 0.06 | JP-8 | API 1993
1,1,3-Trimethylcyclo-hexane | 9 | 8.45 | Aliph2 | 0.48 | JP-4 | API 1993
| | | | 0.05 | JP-5 | API 1993
| | | | 0.06 | JP-8 | API 1993
n-Butylcyclohexane | 10 | | Aliph2 | 0.7 | JP-4 | API 1993
| | | | 0.9 | JP-5 | API 1993
| | | | 0.74 | JP-8 | API 1993
n-Propylcyclohexane | 9 | | Aliph2 | 0.14 | JP-8 | API 1993
Hexylcyclohexane | 12 | | Aliph2 | 0.93 | JP-8 | API 1993
Heptylcyclohexane | 13 | | Aliph2 | 0.99 | JP-5 | API 1993
| | | | 1 | JP-8 | API 1993
Pentylcyclopentane | 10 | 10.4 | Aliph2
1-Trans-2-trans-4-trimethylcyclo-hexane | 9 | | Aliph2 | 0.2 | Crude Oil | API 1993
Straight Chained Alkenes
Propylene | 3
cis-2-Butene | 4 | 4.25 | | 0.13–0.17 | Gasoline | LUFT 1988
trans-2-Butene | 4 | 4.1 | | 0.16–0.20 | Gasoline | LUFT 1988
Pentene-1 | 5 | 4.89 | | 0.33–0.45 | Gasoline | LUFT 1988
1-Pentyne | 5 | 5.13 | Aliph1
cis-2-Pentene | 5 | 5.16 | Aliph1 | 0.43–0.67 | Gasoline | LUFT 1988
Trans-2-pentene | 5 | 5.08 | Aliph1 | 0.52–0.90 | Gasoline | LUFT 1988
1-Hexene | 6 | 5.9 | Aliph1
1-Hexyne | 6 | 6.09 | Aliph1
cis-2-Hexene | 6 | 6.14 | Aliph1 | 0.15–0.24 | Gasoline | LUFT 1988
Trans-2-hexene | 6 | 6.05 | Aliph1 | 0.18–0.36 | Gasoline | LUFT 1988
cis-3-Hexene | 6 | 6.03 | Aliph1 | 0.11–0.13 | Gasoline | LUFT 1988
Trans-3-hexene | 6 | 6.02 | Aliph1 | 0.12–0.15 | Gasoline | LUFT 1988
cis-3-Heptene | 7 | 7.01 | Aliph1 | 0.14–0.17 | Gasoline | LUFT 1988
Trans-2-heptene | 7 | 7.05 | Aliph1 | 0.06–0.10 | Gasoline | LUFT 1988
1-Octene | 8 | 7.89 | Aliph1
1-Nonene | 9 | 8.69 | Aliph2
1-Decene | 10 | 9.91 | Aliph2
Tridecene | 13 | | Aliph2 | 0.45 | JP-5 | API 1993
| | | | 0.73 | JP-8 | API 1993
Branched Chain Alkenes
2-Methyl-1-butene | 5 | 4.96 | | 0.22–0.66 | Gasoline | LUFT 1988
3-Methyl-1-butene | 5 | 4.57 | | 0.08–0.12 | Gasoline | LUFT 1988
2-Methyl-2-butene | 5 | 5.21 | Aliph1 | 0.96–1.28 | Gasoline | LUFT 1988
2,3-Dimethyl-1-butene | 6 | 5.7 | Aliph1 | 0.08–0.10 | Gasoline | LUFT 1988
2-Methyl-1-pentene | 6 | 5.89 | Aliph1 | 0.20–0.22 | Gasoline | LUFT 1988
2,3-Dimethyl-1-pentene | 7 | | Aliph1 | 0.01–0.02 | Gasoline | LUFT 1988
2,4-Dimethyl-1-pentene | 7 | 6.48 | Aliph1 | 0.02–0.03 | Gasoline | LUFT 1988
4,4-Dimethyl-1-pentene | 7 | | Aliph1 | 0.60 (vol) | Gasoline | LUFT 1988
2-Methyl-2-pentene | 6 | 6.07 | Aliph1 | 0.27–0.32 | Gasoline | LUFT 1988
3-Methyl-cis-2-pentene | 6 | 6.11 | Aliph1 | 0.35–0.45 | Gasoline | LUFT 1988
3-Methyl-trans-2-pentene | 6 | 6.22 | Aliph1 | 0.32–0.44 | Gasoline | LUFT 1988
4-Methyl-cis-2-pentene | 6 | 5.69 | Aliph1 | 0.04–0.05 | Gasoline | LUFT 1988
4-Methyl-trans-2-pentene | 6 | 5.73 | Aliph1 | 0.08–0.30 | Gasoline | LUFT 1988
4,4-Dimethyl-cis-2-pentene | 7 | 6.47 | Aliph1 | 0.02 | Gasoline | LUFT 1988
4,4-Dimethyl-trans-2-pentene | 7 | 6.23 | Aliph1 | Not quantified | Gasoline | LUFT 1988
3-Ethyl-2-pentene | 7 | 7.07 | Aliph1 | 0.03–0.04 | Gasoline | LUFT 1988
Cycloalkenes
Cyclopentene | 5 | 5.55 | Aliph1 | 0.12–0.18 | Gasoline | LUFT 1988
3-Methylcyclopentene | 6 | 6.1 | Aliph1 | 0.03–0.08 | Gasoline | LUFT 1988
Cyclohexene | 6 | 6.74 | Aliph1 | 0.03 | Gasoline | LUFT 1988
Alkyl Benzenes
Benzene | 6 | 6.5 | Arom1 | 0.12–3.50 | Gasoline | LUFT 1988
| | | | 0.04–0.4 | Crude Oil | API 1993
| | | | 0.5 | JP-4 | API 1993
| | | | 0.003–0.10 | Diesel | BP 1996
| | | | <0.125 | Fuel Oil #2 | BP 1996
Toluene | 7 | 7.58 | Arom1 | 2.73–21.80 | Gasoline | LUFT 1988
| | | | 0.09–2.5 | Crude Oil | API 1993
| | | | 1.33 | JP-4 | API 1993
| | | | 0.007–0.70 | Diesel | BP 1996
| | | | 0.025–0.110 | Fuel Oil #2 | BP 1996
Ethylbenzene | 8 | 8.5 | Arom1 | 0.36–2.86 | Gasoline | LUFT 1988
| | | | 0.09–0.31 | Crude Oil | API 1993
| | | | 0.37 | JP-4 | API 1993
| | | | 0.007–0.20 | Diesel | BP 1996
| | | | 0.028–0.04 | Fuel Oil #2 | BP 1996
o-Xylene | 8 | 8.81 | Arom1 | 0.68–2.86 | Gasoline | LUFT 1988
| | | | 0.03–0.68 | Crude Oil | API 1993
| | | | 1.01 | JP-4 | API 1993
| | | | 0.09 | JP-5 | API 1993
| | | | 0.06 | JP-8 | API 1993
| | | | 0.001–0.085 | Diesel | BP 1996
m-Xylene | 8 | 8.6 | Arom1 | 1.77–3.87 | Gasoline | LUFT 1988
| | | | 0.08–2.0 | Crude Oil | API 1993
| | | | 0.96 | JP-4 | API 1993
| | | | 0.13 | JP-5 | API 1993
| | | | 0.06 | JP-8 | API 1993
| | | | 0.018–0.512 | Diesel | BP 1996
p-Xylene | 8 | 8.61 | Arom1 | 0.77–1.58 | Gasoline | LUFT 1988
| | | | 0.09–0.68 | Crude Oil | API 1993
| | | | 0.35 | JP-4 | API 1993
| | | | 0.018–0.512 | Diesel | BP 1996
Styrene | 9 | 8.83 | Arom1 | <.002 | Diesel | BP 1996
1-Methyl-4-ethylbenzene | 9 | 9.57 | Arom2 | 0.18–1.00 | Gasoline | LUFT 1988
| | | | 0.03–0.13 | Crude Oil | API 1993
| | | | 0.43 | JP-4 | API 1993
1-Methyl-2-ethylbenzene | 9 | 9.71 | Arom2 | 0.19–0.56 | Gasoline | LUFT 1988
| | | | 0.01–0.09 | Crude Oil | API 1993
| | | | 0.23 | JP-4 | API 1993
1-Methyl-3-ethylbenzene | 9 | 9.55 | Arom2 | 0.31–2.86 | Gasoline | LUFT 1988
| | | | 0.04–0.4 | Crude Oil | API 1993
| | | | 0.49 | JP-4 | API 1993
1-Methyl-2-n-propylbenzene | 10 | | Arom2 | 0.01–0.17 | Gasoline | LUFT 1988
1 -Methyl-3-n-propylbenzene | 10 | | Arom2 | 0.08–0.56 | Gasoline | LUFT 1988
1- Methyl-2-isopropylbenzene | 10 | | Arom2 | 0.01–0.12 | Gasoline | LUFT 1988
| | | | 0.29 | JP-4 | API 1993
| | | | 0.56 | JP-8 | API 1993
1-Methyl-3-isopropylbenzene | 10 | | Arom2 | 10.09
1-Methyl-4-isopropylbenzene | 10 | 10.13 | Arom2 | 0.003–0.026 | Diesel | BP 1996
1-Methyl-3-t-butylbenzene | 11 | | Arom2 | 0.03–0.11 | Gasoline | LUFT 1988
1-Methyl-4-t-butylbenzene | 11 | 10.92 | Arom2 | 0.04–0.13 | Gasoline | LUFT 1988
1,2-Dimethyl-3-ethylbenzene | 10 | 10.93 | Arom2 | 0.02–0.19 | Gasoline | LUFT 1988
1,2-Dimethyl-4-ethylbenzene | 10 | 10.75 | Arom2 | 0.50–0.73 | Gasoline | LUFT 1988
| | | | 0.77 | JP-4 | API 1993
1,3-Dimethyl-2-ethyl-benzene | 10 | 10.81 | Arom2 | 0.21–0.59 | Gasoline | LUFT 1988
1,3-Dimethyl-4-ethylbenzene | 10 | 10.75 | Arom2 | 0.03–0.44 | Gasoline | LUFT 1988
1,3-Dimethyl-5-ethylbenzene | 10 | 10.51 | Arom2 | 0.11–0.42 | Gasoline | LUFT 1988
| | | | 0.61 | JP-4 | API 1993
| | | | 0.62 | JP-8 | API 1993
1,3-Dimethyl-5-t-butylbenzene | 12 | | Arom2 | 0.02–0.16 | Gasoline | LUFT 1988
1,4-Dimethyl-2-ethylbenzene | 10 | 10.68 | Arom2 | 0.05–0.36 | Gasoline | LUFT 1988
| | | | 0.7 | JP-4 | API 1993
1,2,3-Trimethylbenzene | 9 | 10.06 | Arom2 | 0.21–0.48 | Gasoline | LUFT 1988
| | | | 0.1 | Crude Oil | API 1993
1,2,4-Trimethylbenzene | 9 | 9.84 | Arom2 | 0.66–3.30 | Gasoline | LUFT 1988
| | | | 0.13–0.69 | Crude Oil | API 1993
| | | | 1.01 | JP-4 | API 1993
| | | | 0.37 | JP-5 | API 1993
| | | | 0.27 | JP-8 | API 1993
1,3,5-Trimethylbenzene | 9 | 9.62 | Arom2 | 0.13–1.15 | Gasoline | LUFT 1988
| | | | 0.05–0.18 | Crude Oil | API 1993
| | | | 0.42 | JP-4 | API 1993
| | | | 0.09–0.24 | Diesel | BP 1996
1,2,3,4-Tetramethylbenzene | 10 | 11.57 | Arom2 | 0.02–0.19 | Gasoline | LUFT 1988
| | | | 0.2 | Crude Oil | API 1993
1,2,3,5-Tetramethylbenzene | 10 | 11.09 | Arom2 | 0.14–1.06 | Gasoline | LUFT 1988
1,2,4,5-Tetramethylbenzene | 10 | 11.05 | Arom2 | 0.05–0.67 | Gasoline | LUFT 1988
1,2-Diethylbenzene | 10 | 10.52 | Arom2 | 0.57 | Gasoline | LUFT 1988
1,3-Diethylbenzene | 10 | 10.4 | Arom2 | 0.05–0.38 | Gasoline | LUFT 1988
| | | | 0.46 | JP-4 | API 1993
| | | | 0.61 | JP-5 | API 1993
1,4-Diethylbenzene | 10 | 10.46 | Arom2 | 0.77 | JP-5 | API 1993
1,2,4-Triethylbenzene | 12 | 12.29 | Arom2 | 0.72 | JP-5 | API 1993
| | | | 0.99 | JP-8 | API 1993
1,3,5-Triethylbenzene | 12 | 12.1 | Arom2 | 0.6 | JP-8 | API 1993
n-Propylbenzene | 9 | 9.47 | Arom2 | 0.08–0.72 | Gasoline | LUFT 1988
| | | | 0.71 | JP-4 | API 1993
| | | | 0.03–0.048 | Diesel | BP 1996
Isopropylbenzene | 9 | 9.13 | Arom2 | <10.01–0.23 | Gasoline | LUFT 1988
| | | | 0.3 | JP-4 | API 1993
| | | | <0.01 | Diesel | BP 1996
n-Butylbenzene | 10 | 10.5 | Arom2 | 0.04–0.44 | Gasoline | LUFT 1988
| | | | 0.031–0.046 | Diesel | BP 1996
Isobutylbenzene | 10 | 9.96 | Arom2 | 0.01–0.08 | Gasoline | LUFT 1988
sec-Butylbenzene | 10 | 9.98 | Arom2 | 0.01–0.13 | Gasoline | LUFT 1988
t-Butylbenzene | 10 | 9.84 | Arom2 | 0.12 | Gasoline | LUFT 1988
1-t-Butyl-3,4,5-trimethylbenzene | 13 | | Arom2 | 0.24 | JP-5 | API 1993
n-Pentylbenzene | 11 | 11.49 | Arom2 | 0.01–0.14 | Gasoline | LUFT 1988
Isopentylbenzene | 11 | | Arom2 | 0.07–0.17 | Gasoline | LUFT 1988
n-Hexylbenzene | 12 | 12.5 | Arom2
n-Heptylbenzene | 13 | | Arom2 | 0.27 | JP-5 | API 1993
| | | | 0.25 | JP-8 | API 1993
n-Octylbenzene | 14 | | Arom2 | 0.78 | JP-5 | API 1993
| | | | 0.61 | JP-8 | API 1993
Biphenyl | 12 | 14.26 | Arom2 | 0.006-.04 | Crude Oil | API 1993
| | | | 0.7 | JP-5 | API 1993
| | | | 0.63 | JP-8 | API 1993
| | | | 0.01–0.12 | Diesel | BP 1996
| | | | 0.006–0.009 | Fuel Oil #2 | BP 1996
4-Methylbiphenyl | 13 | 14.92 | Arom2
4,4’-Dimethylbiphenyl | 14 | 16.55 | Arom3
Phenylcyclohexane | 12 | | Arom2 | 0.82 | JP-5 | API 1993
| | | | 0.87 | JP-8 | API 1993
Naphtheno-Benzenes
Acenaphthene | 12 | 15.5 | Arom2 | 0.013–0.022 | Fuel Oil #2 | BP 1996
Acenaphthylene | 12 | 15.06 | Arom2 | 0.006 | Fuel Oil #2 | BP 1996
Indan | 9 | 10.27 | Arom2 | 0.25–0.34 | Gasoline | LUFT 1988
| | | | 0.07 | Crude Oil | API 1993
1-Methylindan | 10 | | Arom2 | 0.04–0.17 | Gasoline | LUFT 1988
2-Methylindan | 10 | 11.39 | Arom2 | 0.02–0.10 | Gasoline | LUFT 1988
4-Methylindan | 10 | 11.33 | Arom2 | 0.01–0.16 | Gasoline | LUFT 1988
5-Methylindan | 10 | 11.28 | Arom2 | 0.09–0.30 | Gasoline | LUFT 1988
Tetralin (tetrahydronaphthalene) | 10 | 11.7 | Arom2 | 0.01–0.14 | Gasoline | LUFT 1988
| | | | 0.03 | Crude Oil | API 1993
5-Methyl-thtrohydronaphthalene | 11 | | Arom2 | 0.08 | Crude Oil | API 1993
6-Methylthtrohydrnaphthalene | 11 | | Arom2 | 0.09 | Crude Oil | API 1993
Fluorene | 13 | 16.55 | Arom3 | 0.003–0.06 | Crude Oil | API 1993
| | | | 0.034–0.15 | Diesel | BP 1996
| | | | 0.004–0.045 | Fuel Oil #2 | BP 1996
1-Methylfluorene | 14 | 17.99 | Arom3
Fluoranthene | 16 | 21.85 | Arom3 | 0.0000007–0.02 | Diesel | BP 1996
| | | | 0.000047–0.00037 | Fuel Oil #2 | BP 1996
2,3-Benzofluorene | 17 | 23.83 | Arom3
1,2-Benzofluorene | 17 | 24.2 | Arom3 | <0.0024 | Fuel Oil #2 | BP 1996
Benzo(a)fluorene | 17 | | Arom3 | <0.0006 | Fuel Oil #2 | BP 1996
Benzo(ghi)fluoranthene | 18 | | Arom3 | <0.0024 | Fuel Oil #2 | BP 1996
Benz(b)fluoranthene | 20 | 30.14 | Arom3 | 0.0000003–0.000194 | Diesel | BP 1996
| | | | <0.0024 | Fuel Oil #2 | BP 1996
Benz(k)fluoranthene | 20 | 30.14 | Arom3 | 0.0000003–0.000195 | Diesel | BP 1996
| | | | <0.00006 | Fuel Oil #2 | BP 1996
Indeno (1,2,3-cd) pyrene | 22 | 35.01 | Arom3 | 0.000001–0.000097 | Diesel | BP 1996
| | | | <0.0012 | Fuel Oil #2 | BP 1996
Alkyl Naphthalenes
Naphthalene | 10 | 11.69 | Arom2 | 0.09–0.49 | Gasoline | LUFT 1988
| | | | 0.02–0.09 | Crude Oil | API 1993
| | | | 0.5 | JP-4 | API 1993
| | | | 0.57 | JP-5 | API 1993
| | | | 1.14 | JP-8 | API 1993
| | | | 0.01–0.80 | Diesel | BP 1996
| | | | 0.009–0.40 | Fuel Oil #2 | BP 1996
1-Methylnaphthalene | 11 | 12.99 | Arom2 | 0.78 | JP-4 | API 1993
| | | | 1.44 | JP-5 | API 1993
| | | | 1.84 | JP-8 | API 1993
| | | | 0.001–0.81 | Diesel | BP 1996
| | | | 0.29–0.48 | Fuel Oil #2 | BP 1996
2-Methylnaphthalene | 11 | 12.84 | Arom2 | 0.56 | JP-4 | API 1993
| | | | 1.38 | JP-5 | API 1993
| | | | 1.46 | JP-8 | API 1993
| | | | 0.001–1.49 | Diesel | BP 1996
| | | | 0.36 -1.00 | Fuel Oil #2 | BP 1996
1,3-Dimethylnaphthalene | 12 | 14.77 | Arom2 | 0.55–1.28 | Diesel | BP 1996
1,4-Dimethylnaphthalene | 12 | 14.6 | Arom2 | 0.110–0.23 | Diesel | BP 1996
| | | | 0.043–0.045 | Fuel Oil #2 | BP 1996
1,5-Dimethylnaphthalene | 12 | 13.87 | Arom2 | 0.16–0.36 | Diesel | BP 1996
2,3-Dimethylnaphthalene | 12 | 15 | Arom2 | 0.46 | JP-5 | API 1993
| | | | 0.36 | JP-8 | API 1993
2,6-Dimethylnaphthalene | 12 | 14.6 | Arom2 | 0.25 | JP-4 | API 1993
| | | | 1.12 | JP-5 | API 1993
| | | | 1.34 | JP-8 | API 1993
1-Ethylnaphthalene | 12 | 14.41 | Arom2 | 0.32 | JP-5 | API 1993
| | | | 0.33 | JP-8 | API 1993
2-Ethylnaphthalene | 12 | 13.99 | Arom2
1,4,5-Trimethylnaphthalene | 13 | 10.6 | Arom2
1-Phenylnaphthalene | 16 | | Arom3
Polynuclear Aromatics
Anthracene | 14 | 19.43 | Arom3 | 0.000003 –0.02 | Diesel | BP 1996
| | | | 0.00010–0.011 | Fuel Oil #2 | BP 1996
2-Methyl anthracene | 15 | 20.73 | Arom3 | 0.000015–0.018 | Diesel | BP 1996
| | | | 0.009–0.017 | Fuel Oil #2 | BP 1996
9-Methyl anthracene | 15 | 20.45 | Arom3
2-Ethyl anthracene | 16 | | Arom3
9,10-Dimethyl anthracene | 16 | | Arom3 | 0.002–0.006 | Fuel Oil #2 | BP 1996
Phenanthrene | 14 | 19.36 | Arom3 | 0.003–0.05 | Crude Oil | API 1993
| | | | 0.000027–0.30 | Diesel | BP 1996
| | | | 0.009 –0.170 | Fuel Oil #2 | BP 1996
1-Methylphenanthrene | 15 | 20.73 | Arom3 | 0.000011–0.024 | Diesel | BP 1996
| | | | 0.017 | Fuel Oil #2 | BP 1996
2-Methylphenanthrene | 15 | | Arom3 | 0.014–0.18 | Diesel | BP 1996
| | | | 0.768 | Fuel Oil #2 | BP 1996
3-Methylphenanthrene | 15 | | Arom3 | 0.000013–0.011 | Diesel | BP 1996
4- & 9-Methylphenanthrene | 15 | | Arom3 | 0.00001–0.034 | Diesel | BP 1996
Pyrene | 16 | 20.8 | Arom3 | Not quantified | Gasoline | LUFT 1988
| | | | 0.000018–0.015 | Diesel | BP 1996
| | | | 0.00–0.012 | Fuel Oil #2 | BP 1996
1-Methylpyrene | 17 | | Arom3 | 0.0000024–0.00137 | Diesel | BP 1996
2-Methylpyrene | 17 | | Arom3 | 0.0000037–0.00106 | Diesel | BP 1996
Benz(a)anthracene | 18 | 26.37 | Arom3 | Not quantified | Gasoline | LUFT 1988
| | | | 0.0000021–0.00067 | Diesel | BP 1996
| | | | 0.000002–0.00012 | Fuel Oil #2 | BP 1996
Chrysene | 18 | 27.41 | Arom3 | 0.000045 | Diesel | BP 1996
| | | | 0.000037–0.00039 | Fuel Oil #2 | BP 1996
Triphenylene | 18 | 26.61 | Arom3 | 0.00033 | Diesel | BP 1996
| | | | 0.00002–0.00014 | Fuel Oil #2 | BP 1996
Cyclopenta(cd)pyrene | 18 | | Arom3 | 0.000002–0.0000365 | Diesel | BP 1996
1-Methyl-7-isopropylphenanthrene | 18 | | Arom3 | 0.0000015–0.00399 | Diesel | BP 1996
3-Methylchrysene | 19 | | Arom3 | <0.001 | Diesel | BP 1996
5-Methylchrysene | 19 | | Arom3
6-Methylchrysene | 19 | | Arom3 | <0.0005 | Diesel | BP 1996
Benzo(a)pyrene | 20 | 31.34 | Arom3 | 0.000019–0.00028 | Gasoline | LUFT 1988
| | | | 0.000005–0.00084 | Diesel | BP 1996
| | | | 0.000001–0.000060 | Fuel Oil #2 | BP 1996
Benz(e)pyrene | 20 | 31.17 | Arom3 | Not quantified | Gasoline | LUFT 1988
| | | | 0.0000054–0.000240 | Diesel | BP 1996
| | | | 0.0000020–0.000010 | Fuel Oil #2 | BP 1996
Benzo(ghi)pyrene | 20 | | Arom3 | 0.0000010–0.0000070 | Fuel Oil #2 | BP 1996
Perylene | 20 | 31.34 | Arom3 | <0.0001 | Diesel | BP 1996
| | | | <0.0024 | Fuel Oil #2 | BP 1996
3-Methylcholanthrene | 21 | | Arom3 | <0.00006 | Fuel Oil #2 | BP 1996
Benzo(b)chrysene | 22 | | Arom3 | <0.0036 | Fuel Oil #2 | BP 1996
Benz(ghi)perylene | 22 | 34.01 | Arom3 | Not quantified | Gasoline | LUFT 1988
| | | | 0.0000009–0.00004 | Diesel | BP 1996
| | | | 20.0000057 | Fuel Oil #2 | BP 1996
Picene | 22 | | Arom3 | 0.0000004–0.000083 | Diesel | BP 1996
| | | | <0.00012 | Fuel Oil #2 | BP 1996
1,2,5,6-Dibenzanthracene | 22 | 33.92 | Arom3
Coronene | 24 | 34.01 | Arom3 | <0.000024 | Fuel Oil #2 | BP 1996

a Effective Carbon Number Index

b Aliph1 = Aliphatics EC_5_-EC_8_; Arom1 = Aromatics EC_5_-EC_9_

Aliph2 = Aliphatics EC_>8_-EC_16_; Arom2 = Aromatics EC_>9_-EC_16_

Aliph3 = Aliphatics EC_>18_-EC_35_; Arom3 = Aromatics EC_>16_-EC_35_

Source: Total Petroleum Hydrocarbons Criteria Working Group. 1997. Selection of Representative TPH Fractions Based on Fate and Transport Considerations, vol. 3.