# APPENDIX C ACRONYMS, ABBREVIATIONS, AND SYMBOLS

ACGIH: American Conference of Governmental Industrial Hygienists
ADME: Absorption, Distribution, Metabolism, and Excretion
atm: atmosphere
ASTM: American Society for Testing and Materials
ATSDR: Agency for Toxic Substances and Disease Registry
BCF: bioconcentration factor
BSC: Board of Scientific Counselors
BTEX: benzene, toluene, ethylbenzene, xylene
C: Centigrade
CDC: Centers for Disease Control and Prevention
CEL: Cancer Effect Level
CERCLA: Comprehensive Environmental Response, Compensation, and Liability Act
CFR: Code of Federal Regulations
CLP: Contract Laboratory Program
cm: centimeter
CNS: central nervous system
d: day
DHEW: Department of Health, Education, and Welfare
DHHS: Department of Health and Human Services
DNAPL: denser nonaqueous phase liquids
DOL: Department of Labor
EC: equivalent carbon number
ECG: electrocardiogram
EEG: electroencephalogram
EPA: Environmental Protection Agency
EKG: see ECG
DRO: diesel range organics
F: Fahrenheit
F_1_: first filial generation
FAO: Food and Agricultural Organization of the United Nations
FEMA: Federal Emergency Management Agency
FID: flame ionization detection
FIFRA: Federal Insecticide, Fungicide, and Rodenticide Act
fpm: feet per minute
ft: foot
FR: Federal Register
g: gram
GC: gas chromatography
GC/MS: gas chromatography/mass spectrometry
gen: generation
GRO: gasolines range organics
HEC: human equivalent concentration
HPLC: high-performance liquid chromatography
hr: hour
HSSM: hydrocarbon spill screening model
IDLH: Immediately Dangerous to Life and Health
IARC: International Agency for Research on Cancer
IOC: index of concern
ILO: International Labor Organization
in: inch
Kd: adsorption ratio
Kg: kilogram
KKg: metric ton
K_oc_: organic carbon partition coefficient
K_ow_: octanol-water partition coefficient
L: liter
LC: liquid chromatography
LC_LO_: lethal concentration, low
LC_50_: lethal concentration, 50% kill
LD_LO_: lethal dose, low
LD_50_: lethal dose, 50% kill
LNAPL: lighter nonaqueous phase liquids
LOAEL: lowest-observed-adverse-effect level
LSE: Levels of Significant Exposure
LUST: leaking underground storage tanks
m: meter
MADEP: Massachusetts Department of Environmental Protection
MARPOL: International Convention for the Prevention of Pollution Ships (marine pollution)
mg: milligram
min: minute
mL: milliliter
mm: millimeter
mmHg: millimeters of mercury
MTBE: methyl-terf-butyl ether
mmol: millimole
mo: month
mppcf: millions of particles per cubic foot
MRL: Minimal Risk Level
MS: mass spectrometry
NAPL: non-aqueous phase liquids
NIEHS: National Institute of Environmental Health Sciences
NIOSH: National Institute for Occupational Safety and Health
NIOSHTIC: NIOSH's Computerized Information Retrieval System
ng: nanogram
nm: nanometer
NHANES: National Health and Nutrition Examination Survey
nmol: nanomole
NOAEL: no-observed-adverse-effect level
NOES: National Occupational Exposure Survey
NOHS: National Occupational Hazard Survey
NPDES: National Pollutant Discharge Elimination System
NPL: National Priorities List
NRC: National Research Council
NTIS: National Technical Information Service
NTP: National Toxicology Program
OSHA: Occupational Safety and Health Administration
PAHs: polyaromatic hydrocarbons
PCBs: polychlorinated biphenyls
PEL: permissible exposure limit
pg: picogram
PID: photo ionization detector
pmol: picomole
PHS: Public Health Service
PMR: proportionate mortality ratio
ppb: parts per billion
ppm: parts per million
ppt: parts per trillion
RBCA: Risk-Based Corrective Action
RBSL: risk-based screening level
RCRA: Resource Conservation and Recovery Act
REL: recommended exposure limit
RfC: Reference Concentration
RfD: Reference Dose
RP: relative potency
RQ: reportable quantity
RTECS: Registry of Toxic Effects of Chemical Substances
sec: second
SCE: sister chromatid exchange
SFE: supercritical fluid extraction
SIC: Standard Industrial Classification
SMR: standard mortality ratio
spcc: spill prevention, control and countermeasure
SPE: solid phase extraction
SSTL: site-specific target level
STEL: short term exposure limit
STORET: STORAGE and RETRIEVAL
TOG: total recoverable oil and grease
TPH: total petroleum hydrocarbons
TPHCWG: Total Petroleum Hydrocarbons Criteria Working Group
TRPH: total recoverable petroleum hydrocarbons
TSCA: Toxic Substances Control Act (TSCA)
TLV: threshold limit value
TSCA: Toxic Substances Control Act
TSDF: treatment, storage and disposal facilities, hazardous wastes
TRI: Toxics Release Inventory
TWA: time-weighted average
U.S.: United States
UF: uncertainty factor
UST: underground storage tank
yr: year
WHO: World Health Organization
wK: week
WOE: weight-of-evidence, classification of carcinogenicity

>: greater than
≥: greater than or equal to
=: equal to
<: less than
≤: less than or equal to
%: percent
α: alpha
β: beta
δ: delta
γ: gamma
μm: micrometer
μg: microgram