# APPENDIX A MRLS AND CANCER CLASSIFICATION FOR TPH COMPONENTS AND WHOLE PRODUCTS

MRLs listed in Table A-1 are found in Appendix A of the individual Toxicological Profile referenced. Appendix A of each profile describes the basis for ATSDR MRL’s derivation and use and includes worksheets showing calculations used to derive each MRL.

Table A-1 Minimal Risk Levels and Cancer Classification for TPH Components and Whole Products^a^

Chemical | MRL (inhalation) | MRL (oral) | IARC Cancer Classification^b^ | EPA Cancer classification^c^
Automotive gasoline^d^ | NA | NA | NA | NA
Benzene^e^ | 0.05 ppm (acute), 0.004 ppm (intermediate) | NA | Group 1 | Group A
Ethylbenzene^f^ | 0.2 ppm (intermediate) | NA | NA | Group D
Fuel Oils^g^ | 0.02 mg/m^3^ (acute, diesel fuels), 0.01 mg/m^3^ (intermediate, kerosene) | NA | Group 2A: petroleum refining, occupational Group 2B: marine diesel fuels & residual fuel oils Group 3: jet fuels & distillate diesel fuels | NA
n-Hexane^h^ | 0.6 ppm (chronic) | NA | NA | Group D
Jet Fuels^i^ | 9 mg/m^3^ (intermediate, JP-4); 3 mg/m^3^ (intermediate, JP 5/8); 0.3 mg/m^3^ (chronic, JP-7) | NA | Group 3 | NA
Mineral-based Crankcase Oil^j^ | NA | NA | NA | NA
Naphthalene^k^ | 0.002 ppm (chronic, naphthalene) | 0.05 mg/kg/day (acute, naphthalene); 0.02 mg/kg/day (intermediate, naphthalene); 0.07 mg/kg/day (chronic, 1-methylnaphthalene) | Group 3 | Group D
PAHs^l^ | NA | 0.6 mg/kg/day (intermediate, acenaphthene); 0.4 mg/kg/day (intermediate, fluoranthene & fluorene); 10 mg/kg/day (intermediate, anthracene) | Group 2A: benz(a)anthracene, benzo(a)pyrene; Group 2B: benzo(b)fluoranthene benzo(j)fluoranthene, ideno(1,2,3-c,d)pyrene; Group 3: anthracene, benzo(g,h,i)perylene, & additional PAHs | Group B2: benz(a)anthracene, benzo(b)fluoranthene, benzo(a)pyrene, chrysene, dibenz(a,h)-anthracene, indeno(1,2,3-c,d)-pyrene; Group D: acenaphthylene, anthracene, fluoranthene
Toluene^m^ | 3 ppm (acute); 1 ppm (chronic) | 0.8 mg/kg/day (acute); 0.02 mg/kg/day (intermediate) | NA | Group D
Xylenes^n^ | 1 ppm (acute, mixed xylenes); 0.7 ppm (intermediate, mixed xylenes); 0.1 ppm (chronic, mixed xylenes) | 1 mg/kg/day (acute, p-xylene); 0.2 mg/kg/day (intermediate, mixed xylenes); 0.6 mg/kg/day (intermediate, m-xylene) | Group 3 | Group D

NA = not available

a MRLs listed in Table A-1 are found in Appendix A of the individual Toxicological Profile referenced. Appendix A of each profile describes the basis for ATSDR MRL’s derivation and use and includes worksheets showing calculations used to derive each MRL.

b IARC Cancer Classifications: Group 1: carcinogenic to humans, Group 2A: probably carcinogenic to humans, Group 2B: possibly carcinogenic to humans, Group 3: not classifiable as to its carcinogenicity to humans

c EPA Cancer Classifications: Group A; known human carcinogen, Group B2: probable human carcinogen, Group C: possible human carcinogen, Group D; not classifiable as to its carcinogenicity to humans

d ATSDR. 1995a. Toxicological profile for automotive gasoline. Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA. NTIS PB95-264206.

e ATSDR. 1997a. Toxicological profile for benzene (update). Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA.

f ATSDR. 1997b. Toxicological profile for ethylbenzene (draft for public comment). Agency for Toxic

Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA.

g ATSDR. 1995g. Toxicological profile for fuel oils. Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA. NTIS PB95-264222.

h ATSDR. 1997c. Toxicological profile for hexane (draft for public comment). Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA.

i ATSDR. 1995c. Toxicological profile for jet fuels (JP-4 and JP-7). Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA. NTIS PB95-264230.

ATSDR. 1998b. Toxicological profile for jet fuels (JP-5 and JP-8) (February 1998 draft final). Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA.

j ATSDR. 1997e. Toxicological profile for mineral-based crankcase oil. Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA.

k ATSDR. 1995e. Toxicological profile for naphthalene (update). Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA.

l ATSDR. 1995f. Toxicological profile for polycyclic aromatic hydrocarbons (PAHS) (update). Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA.

m ATSDR. 1994. Toxicological profile for toluene (update). Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA. TP-93/14.

n ATSDR. 1995d. Toxicological profile for xylenes (update). Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services, Atlanta, GA.