# 7 ANALYTICAL METHODS

The purpose of this chapter is to describe the analytical methods that are available for detecting, measuring, and/or monitoring toluene, its metabolites, and other biomarkers of exposure and effect to toluene. The intent is not to provide an exhaustive list of analytical methods. Rather, the intention is to identify well-established methods that are used as the standard methods of analysis. Many of the analytical methods used for environmental samples are the methods approved by federal agencies and organizations such as EPA and the National Institute for Occupational Safety and Health (NIOSH). Other methods presented in this chapter are those that are approved by groups such as the Association of Official Analytical Chemists (AOAC) and the American Public Health Association (APHA). Additionally, analytical methods are included that modify previously used methods to obtain lower detection limits and/or to improve accuracy and precision.

## 7.1 BIOLOGICAL MATERIALS

Toluene can be determined in biological fluids and tissues and exhaled breath using a variety of analytical methods. Representative methods are summarized in Table 7-1. Most analytical methods for biological fluids use headspace gas chromatographic (GC) techniques. Breath samples are usually collected on adsorbent traps or in sampling bags or canisters, and then analyzed by GC.

Because of its volatility, toluene is lost from biological samples, such as plant and animal tissue and body fluids, relatively easily. Therefore, samples must be collected and stored with care (e.g., at low temperatures in sealed containers) to prevent analyte loss. While blood sample collection is more invasive than breath or urine samples, maintaining the integrity of blood in the collection, transportation, and storage of the samples is easier. Blood is relatively nonpolar, which results in less diffusion loss (Chambers et al. 2006).

Headspace techniques are usually used to separate toluene from biological fluids such as blood and urine. The headspace method involves equilibrium of volatile analytes such as toluene between a liquid and solid sample phase and the gaseous phase. The gaseous phase is then analyzed by GC. There are two main types of headspace methodology: static (equilibrium) headspace and dynamic headspace which is usually called the “purge and trap” method (Seto 1994). The static headspace technique is relatively simple, but may be less sensitive than the purge-and-trap method. The purge-and-trap method, while providing increased sensitivity, requires more complex instrumentation and may result in artifact formation (Seto 1994). Packed columns and capillary columns are used for chromatographic separation, followed by identification and quantitation using various detectors; flame ionization detection (FID), photoionization detection (PID), and mass spectrometry (MS) are used most often. Other sample preparation methods have been used, but less frequently. Solvent extraction permits concentration, thereby increasing sensitivity, but the extraction solvent can interfere with analysis. Direct aqueous injection is a very rapid method, but sensitivity is low and matrix effects can be a serious problem.

Table 7-1 Analytical Methods for Determining Toluene in Biological Materials

Sample matrix | Preparation method | Analytical method | Sample detection limit | Percent recovery | Reference
Blood | Lyse; extraction with carbon disulfide | GC/FID | No data | No data | Benignus et al. 1981
Blood | Purge and trap | No data | 7.5 μg/L | No data | Cocheo et al. 1982
Whole blood | Purge and trap | GC/MS | 0.088 μg/L | 91–147 | Ashley et al. 1992
Blood | Purge and trap | capillary GC/FID | 50 ng/L | 50 | Fustinoni 1996
Blood | Headspace extraction | capillary GC/ITD | 0.04 μmol/L | No data | Schuberth 1994
Blood | Headspace SPME | GC/MS | 24 pg/mL | No data | Chambers et al. 2006
Mother’s milk | Purge and trap | capillary GC/FID | No data | 63 (chloro-benzene) | Michael et al. 1991; Pellizzari et al. 1982
Urine | Purge and trap | capillary GC/FID | 50 ng/L | 59 | Fustinoni 1996
Urine | Heated headspace extraction | capillary GC/FID | 1 ng/mL | 42.3 | Lee et al. 1998b
Urine | Headspace (Purge and Trap) | GC/PID | 15 ng/L | No data | Skender et al. 2004
Biofluids | Headspace extraction | GC/FID | No data | No data | Suitheimer et al. 1982
Adipose tissue | Evaporation at 150°C into nitrogen, direct gas injection | GC/FID | No data | 88–112 | Carlsson and Ljungquist 1982
Brain tissue | Extraction with carbon disulfide; homogenization; centrifugation | GC/FID | No data | No data | Benignus et al. 1981
Breath | Collection in modified Haldane-Priestly tube; transfer to adsorption tube; thermal desorption | capillary GC/MS | 1 nmole | No data | Dyne et al. 1997
Breath | Collection via spirometer into passivated canisters | capillary GC/MS | low μg/m^3^ | 80–136 | Thomas et al. 1991
Breath | Collection via spirometer into 1.8°L passivated canisters | capillary GC/MS | ~2 μg/m^3^ | 91–104 | Thomas et al. 1992
Breath | Collection via spirometer onto charcoal traps; microwave desorption | capillary GC/MS-SIM | 3 μg/m^3^ | No data | Riedel et al. 1996

FID = flame ionization detector; GC = gas chromatography; ITD = ion trap detection; MS = mass spectrometry; SIM = selected ion monitoring

In addition, the dynamic headspace purge-and-trap GC method with PID was utilized for the determination of toluene in urine samples obtained from participants of Zagreb, Croatia. The detection limit was 15 ng/L (Skender et al. 2004).

Headspace solid phase microextraction (SPME) is a relatively new alternative method to detect nonpolar species in the blood. Chambers et al. (2006) utilized this method, along with GC/MS to detect BTEX in the blood. The authors also improved the technique by minimizing contamination from the vacutainers, disposable syringes and vial septa. The limit of detection for toluene was 25 pg/mL (Chambers et al. 2006).

A sensitive and reliable method for identification and quantitation of toluene in samples of whole blood taken from humans following exposure to volatile organic compounds has been developed by researchers at the Centers for Disease Control and Prevention (Ashley et al. 1992, 1996). The method involves purge-and-trap of a 10 mL blood sample with analysis by capillary GC/MS. Anti-foam procedures were used, as well as special efforts to remove background levels of volatile organic compounds from reagents and equipment (Ashley et al. 1992). The method is sensitive enough (ppt levels) to determine background levels of volatile organic compounds in the population and provides adequate accuracy (91–147% recovery) and precision (12% relative standard deviation [RSD]) for monitoring toluene in the population. Most modern purge and trap methods provide detection limits in the ppt range for toluene in both blood and urine (Ashley et al. 1992; Fustinoni et al. 1996).

Few methods are available for the determination of toluene in other body fluids and tissues. Toluene may be extracted from biological materials using solvents such as carbon disulfide (Benignus et al. 1981); homogenization of tissue with the extractant and lysing of cells improves extraction efficiency. Care must be taken to avoid loss of low-boiling compounds. Highly purified solvents may be used to minimize problems with solvent impurities. A modified dynamic headspace method for urine, mother’s milk, and adipose tissue has been reported (Michael et al. 1980). Volatiles swept from the sample are analyzed by capillary GC/FID. Acceptable recovery was reported for model compounds, but detection limits were not reported (Michael et al. 1980). Supercritical fluid extraction using pure carbon dioxide or carbon dioxide with additives has good potential for the extraction of organic analytes such as toluene from biological samples.

Sensitive, reliable methods are available for measuring toluene in breath. Exhaled breath is collected in modified Haldane-Priestly tubes (Dyne et al. 1997), into passivated canisters (Thomas et al. 1992), or directly onto adsorbent traps (Riedel et al. 1996). The detection limits are in the low μg/m^3^ range (Riedel et al. 1996; Thomas et al. 1991, 1992); accuracy, where reported, is good (≥80%) (Riedel et al. 1996; Thomas et al. 1991, 1992).

Representative methods for determination of biomarkers of exposure to toluene are shown in Table 7-2. Measurement of toluene in blood (Kawai et al. 1993), urine (Kawai et al. 1996) and exhaled air (Lapare et al. 1993) provide reliable markers of exposure to toluene. Measurement of toluene metabolites is also utilized for monitoring toluene exposure in humans. Hippuric acid is formed in the body by the metabolism of toluene, and it is the glycine conjugate of benzoic acid.

High performance liquid chromatography (HPLC) with ultraviolet (UV) detection is usually used for determination of metabolites in urine. Currently, ACGIH (2010, 2013) recommends measuring ortho-cresol levels in the urine at the end of the workshift to assess toluene levels in exposed workers (along with toluene levels in urine at the end of a workshift and toluene levels in blood immediately prior to the last shift of a workweek). Previously, the level of hippuric acid in urine at the end of a workshift was recommended as a biomarker of exposure, but this recommendation was withdrawn because background urinary hippuric acid from consumption of benzoate in foods and beverages is expected to mask contributions from workplace exposure to toluene, especially at concentrations below 50 ppm (ACGIH 2001, 2010). Other metabolites such as benzylmercapturic acid (BMA) (Inoue et al. 2002, 2004; Maestri et al. 1997) or S-p-toluylmercapturic acid (Angerer et al. 1998a, 1998b) may also be measured; however, their usefulness may be limited by variability among individuals. See Section 3.8 (Biomarkers of Exposure and Effect) for more information.

Detection of hippuric acid was done by ^1^H NMR Spectroscopy after the samples were prepared by adding deuterium oxide (D_2_O) and sodium trimethylsilyl [2,2,3,3-2H_4_] propionate (TSP) to urine samples of glue abusers (glue sniffers). Toluene is reported as the main component in glue. Hippuric acid levels were the highest after glue sniffing (Kwon et al. 2011).

Table 7-2 Analytical Methods for Determining Biomarkers of Toluene in Biological Samples

Sample matrix | Preparation method | Analytical method | Sample detection limit | Percent recovery | Reference
Blood (toluene) | Headspace | GC | No data | No data | Kawai et al. 1993
Urine (toluene) | Headspace | GC/FID | 2 μg/L | No data | Kawai et al. 1996
Urine (HA) | Extraction with ethyl acetate; evaporation; redissolve in water | HPLC/UV | 30 mg/L | No data | NIOSH 1984b
Urine | Extraction with MTBE, elution with phosphate buffer/methanol/formaldehyde | HPLC | 0.1 mmol | 101 | Tardif et al. 1989
Urine (o-cresol) | Hydrolysis; solvent extraction | HPLC/UV | 0.5 mg/L | 95^a^ | Kawai et al. 1996
Urine | Addition of deuterium oxide and TSP to samples | ^1^H NMR | No data | No data | Kwon et al. 2011
Urine (BMA) | Adsorbent column cleanup; derivatization | HPLC/Fl | 0.5 μg/L | No data | Maestri et al. 1997
Breath | Collection in Tedlar bags | GC/FID | No data | No data | Lapare et al. 1993

a Extraction efficiency.

BMA = benzylmercapturic acid; FID = flame ionization detector; Fl = fluorescence detector; GC = gas chromatography; HA = hippuric acid; HPLC = high performance liquid chromatography; MTBE = methyl tertiary butyl ether; UV = ultraviolet detection

## 7.2 ENVIRONMENTAL SAMPLES

Methods are available for determining toluene in a variety of environmental matrices. A summary of representative methods is shown in Table 7-3. Validated methods, approved by agencies and organizations such as EPA, ASTM, APHA, and NIOSH, are available for air, water, and solid waste matrices. GC is the most widely used analytical technique for quantifying concentrations of toluene in environmental matrices. Various detection devices used for GC include FID, MS, and PID. Because of the complexity of the sample matrix and the usually low concentrations of volatile organic compounds in environmental media, sample preconcentration is generally required prior to GC analysis. Air samples may be collected and concentrated on adsorbent or in canisters for subsequent analysis. Methods suitable for determining trace amounts of toluene in aqueous and other environmental media include three basic approaches to the pretreatment of the sample: gas purge-and-trap technique, headspace gas analysis, and extraction with organic solvent. Purge-and-trap is the most widely used method for the isolation and concentration of volatile organic compounds in environmental samples (Lesage et al. 1993). The purge and trap technique offers advantages over other techniques in that it allows facile isolation and concentration of target compounds, thereby improving overall limits of detection and recovery of sample.

Sampling techniques for air include collection in sample loops, on adsorbent, in canisters, and by cryogenic trapping. The analysis is normally performed by GC/FID, GC/PID, or GC/MS. Detection limits depend on the amount of air sampled, but values in the ppt range have been reported (Dewulf and Van Langenhover 1997).

BTEX was monitored in the urban air of nine sites by use of GC/MS. Toluene concentrations were the highest among the compounds. The limit of detection was also highest for toluene at 1 μg/m^3^ (Nicoara et al. 2009).

Toluene may be determined in occupational air using collection on adsorbent tubes, solvent desorption and GC/FID analysis (NIOSH 1994). Detection limits depend upon the amount of air sampled; accuracy is very good (11.4% bias) (NIOSH 1994).

Campos-Candel et al. (2009) compared HPLC-fluorescence (HPLC-FL) to GC/MS measurements of toluene in air samples. The limit of detection for the samples in HPLC-FL method was 0.5 mg/L or 5 μg/sample and the limit of detection for GC/MS was 0.6 pg/s or 0.08 μg/sample. The GC/MS was deemed to be more sensitive.

Table 7-3 Analytical Methods for Determining Toluene in Environmental Samples

Sample matrix | Preparation method | Analytical method | Sample detection limit | Percent recovery | Reference
Workplace air | Sorption on activated carbon; extraction with carbon disulfide | GC/FID | 0.01 mg | ±11.4^a^ | NIOSH 1994; Method 1501
Workplace air | Sorption on activated charcoal or Radiello diffusive samplers | HPLC | 0.5 mg/L or 5 μg/sample | No data | Campos-Candel et al. 2009
Workplace air | Sorption on activated charcoal or Radiello diffusive samplers | GC/MS | 0.6 pg/s or 0.08 μg/sample | No data | Campos-Candel et al. 2009
Indoor air | Solid phase microextraction (SPME) | GC/MS | 0.004 mg/m^3^ | No data | Gorlo et al. 1999
Air | Sorption onto Tenax^®^; solvent extraction; thermal desorption | GC/MS | <0.88 ppbv | 111–163 | Crist and Mitchell 1986
Air | Sorption onto Tenax^®^; thermal desorption | GC/MS | No data | 93–94 | EPA 1988a; Method TO-1; Krost et al. 1982
Air | Collection in passivated canisters | GC/MS | low ppb | No data | EPA 1988b; Method TO-14
Air | Collection on multisorbent tubes; thermal desorption | GC/MS | No data | No data | EPA 1997a; Method TO-17
Air | Collection in sorbent sampler tubes | GC/FID | 0.01 mg/sample | 94 | USEPA, EMMI 1997; NIOSH 1500
Air | Sorption on activated charcoal; extraction with carbon disulfide | GC/FID | 0.01 mg/sample | No data | USEPA, EMMI 1997; NIOSH 4000
Air | Solid phase membrane samplers (SPMS) | GC/MS | 0.0001 μg/sampler | No data | Esteve-Turrillas et al. 2009
Air | Preconcentration in SKS glass tube with charcoal, desorption | GC/MS | 1 μg/m^3^ | No data | Nicoara et al. 2009
Stack gas effluents | Sorption onto Tenax^®^; thermal desorption | GC/MS | No data | 50–150 | USEPA, EMMI 1997; OSW 5041A
Vehicle exhaust | Direct | GC/FID | 0.5 ppb | No data | Dearth et al. 1992
Drinking water | Purge and trap | capillary GC/PID | 0.01–0.02 ppb | 98–99 | DeMarini et al. 1991; EPA 1991a; Method 502.2
Drinking water | Purge and trap | GC/PID | 0.02 ppb | 94 | EPA 1991b; Method 503.1
Drinking water | Purge and trap | capillary GC/MS | 0.08– 0.11 ppb | 100–126 | EPA 1992a; Method 524.2
Water/waste water | Purge and trap | GC/PID | 0.2 ppb | 77 | EPA 1982a; Method 602
Water/waste water | Purge and trap | GC/MS | 6.0 ppb | 98–101 | EPA 1982b; Method 624
Water/waste water | Addition of isotopically labeled analog; purge and trap | GC/MS | 10 ppb | No data | EPA 1984; Method 1624
Industrial effluents | Purged with inert gas onto Tenax®; thermally desorbed | GC/IDMS | 20 ppb | No data | Colby et al. 1980
Drinking water, waste water | Purged with inert gas onto Tenax®; thermally desorbed, cryofocused | GC/MS | 1 ppb | 74–107 | Michael et al. 1988
Groundwater | Solid-phase microextraction | GC/FID | 2 ppb | No data | Arthur et al. 1992
Water | Purge and trap | GC/MS | 0.047 ppb | 106 | USEPA, EMMI 1997; APHA 6210-B
Water | Direct aqueous injection | GC | 1.0 ppm | No data | USEPA, EMMI 1997; ASTM D3695
Water | Purge and trap | GC | 0.5 ppb | 80–120 | USEPA, EMMI 1997; APHA 6220-B
Water | Dilution in appropriate solvent | FS | 2.1 ppm | No data | USEPA, EMMI 1997; ASTM D4763
Water | Static mode sampling | IMS | No data | No data | Wan et al. 1998
Groundwater, aqueous sludges, waste solvents, acid and caustic liquors, soils, sediments | Purge and trap | GC/MS | 5 ppb | 47–150 | USEPA, EMMI 1997; OSW8240B-W
Groundwater, aqueous sludges, waste solvents, acid and caustic liquors, soils, sediments | Purge and trap or direct injection | GC/EC or GC/PID | 0.01 ppb | 99 | USEPA, EMMI 1997; OSW 8021B-PID
Solid waste | Purge-and-trap | capillary GC/PID | 0.01 ppb | 99 | EPA 1996a; Method 8021B
Solid waste | Purge-and-trap | GC/PID | 0.08–0.11 ppb | 100–102 | EPA 1996b; Method 8260B
Solid waste | Static Headspace sampling (HS) | GC/MS | 0.72 ng/L | 101 | Bernado et al. 2009
Soil | Methanol extraction; SPE | capillary GC | sub-ppm | >90 | Meney et al. 1998
Soil (screening) | Filter | immunoas say | 7 ppm | No data | EPA 1996c; Method 4030
Soils and sediments | Headspace extraction | GC/PID | 0.2 ppb | 46–148 | USEPA, EMMI 1997; OSW 8020A
Soils and other solid matrices | Headspace extraction | GC/FID; GC/PID/ELCD | No data | No data | USEPA, EMMI 1997; OSW 5021
Solid waste matrices | Purge and trap or direct aqueous injection or concentration by azeotropic distillation or automated static headspace | GC/MS | 0.11 ppb | 102 | USEPA, EMMI 1997; OSW 8260B
Plant cuticle | Headspace extraction | GC/FID | No data | No data | Keymeulen et al. 1997
Food | Headspace extraction, 1 hour at 90°C | GC | No data | No data | Walters 1986
Foods | Purge and trap | capillary GC/MS | 8 ppb | 54–76^b^ | Heikes et al. 1995
Bottled water | Headspace extraction | GC/MS | 0.5–1 ppb | No data | Page et al. 1993
Olive oil | Homogenization; headspace | capillary GC/MS | No data | No data | Biedermann et al. 1995

a Reported accuracy.

b Intralaboratory accuracy. Single lab accuracy is reported as 100–106% recovery.

ELCD = electrolytic conductivity detector; FID = flame ionization detector; FS = fluorescence spectroscopy; GC = gas chromatography; IDMS = isotope dilution mass spectrometry; MS = mass spectrometry; PID = photoionization detector; SPE = solid-phase extraction

Esteve-Turrillas et al. (2009) developed a versatile, easy, and rapid atmosphere monitor (V-E-R-A-M) for the detection of BTEX in the air. Solid-phase membrane samplers (SPMS) and HS-GC-MS were utilized for the study. The limit of detection was determined to be 0.001 μg/sampler.

Older studies have suggested that passive samplers were utilized in the detection of toluene, but performance data on those samplers were unavailable (Ballesta et al. 1992; Periago et al. 1997). Newer studies demonstrate the efficacy of these samplers. SPME, a passive sampling method, was utilized to detect toluene in the indoor air in freshly renovated flats. The detection limit was 0.004 mg/m^3^ (Gorlo et al. 1999).

Gas purge and trap is the most widely used method for the isolation and concentration of volatile organic compounds in environmental samples (Lesage et al. 1993). The purge and trap technique offers advantages over other techniques in that it allows facile isolation and concentration of target compounds, thereby improving overall limits of detection and recovery of sample. Detection limits of less than 1 μg of toluene per liter of sample have been achieved. Very low detection limits for drinking water are reported for the purge and trap method with GC/PID (0.01–0.02 ppb) (DeMarini et al. 1991, EPA 1991a). Accuracy is very good (94–99% recovery) (DeMarini et al. 1991, EPA 1991a). While the analytical method is selective, confirmation using a second column or GC/MS is recommended (EPA 1992a). Good sensitivity (0.08–0.11 ppb) and accuracy (100–126% recovery) can also be obtained using capillary GC/MS detection (EPA 1992a). Purge-and-trap methodology may be applied to waste water as well (EPA 1982a, 1982b, 1984). Sensitivity is in the low ppb range and recovery is good (77–101%) (EPA 1982a, 1982b, 1984).

Ion mobility spectrometry (IMS) was used in the detection of BTEX compounds in water. Static mode sampling determined the toluene concentration of 0.101 mg/L in purified water, which resulted in a headspace concentration of 2.75 μg/m^3^ (Wan et al. 1998).

Soil, sediment, and solid waste are more difficult to analyze. Volatilization during sample handling and homogenization can result in analyte loss. Purge-and-trap methods with capillary GC/PID or GC/MS analysis provide detection limits of approximately 0.5 ppm for wastes and 5 μg/g for soil and sediment (EPA 1982a, 1982b, 1984). Static headspace sampling (HS), along with GC-MS, was utilized in a study conducted by Bernardo et al. (2009) to effectively detect toluene in solid residues (waste) produced from the co-pyrolysis of plastics and pine biomass. The detection limit was 0.72 ng/L.

No methods were found for the determination of toluene in fish and biota. Few methods are available for the determination of toluene in food. A purge and trap extraction method is available for determining toluene in a variety of foods. The quantitation limit is 8 ppb; single lab recovery is very good (100–106%) and precision is good (9.8–25% RSD). Both intra- and inter-laboratory studies were conducted, and precision was found to be ≤25% RSD (Heikes et al. 1995).

## 7.3 ADEQUACY OF THE DATABASE

Section 104(i)(5) of CERCLA, as amended, directs the Administrator of ATSDR (in consultation with the Administrator of EPA and agencies and programs of the Public Health Service) to assess whether adequate information on the health effects of toluene is available. Where adequate information is not available, ATSDR, in conjunction with NTP, is required to assure the initiation of a program of research designed to determine the health effects (and techniques for developing methods to determine such health effects) of toluene.

The following categories of possible data needs have been identified by a joint team of scientists from ATSDR, NTP, and EPA. They are defined as substance-specific informational needs that if met would reduce the uncertainties of human health assessment. This definition should not be interpreted to mean that all data needs discussed in this section must be filled. In the future, the identified data needs will be evaluated and prioritized, and a substance-specific research agenda will be proposed.

### 7.3.1 Identification of Data Needs

Methods for Determining Biomarkers of Exposure and Effect. Although toluene and its metabolites can be measured in body fluids using a number of techniques (Kawai et al. 1993, 1996; NIOSH 1984a), some of the metabolites have limited value as biomarkers. A number of common food materials produce the same metabolites; thus, measurement of toluene metabolites can be used to confirm a known exposure but cannot be used to determine whether or not exposure occurred in a poorly defined situation. It is also very difficult to quantify the magnitude of exposure from levels of either toluene or its metabolites in biological samples. Currently, ACGIH (2010, 2013) recommends using a combination of three biological exposure indices (BEIs^®^) to assess exposure of workers to toluene in the workplace: (1) ortho-cresol levels in the urine at the end of the workshift; (2) toluene levels in urine at the end of a workshift; and (3) toluene levels in blood immediately prior to the last shift of a workweek). The specific values for these BEIs^®^ correspond to concentrations likely to be observed in individuals exposed by inhalation to 20 ppm, the current ACGIH 8-hour TWA Threshold Limit Value (TWA-TLV^®^) for occupational exposure to toluene (ACGIH 2010). A technique that could more accurately quantify exposure to toluene in biological fluids may be useful.

Exposure. Additional research to develop more sensitive methods for analysis of toluene and metabolites may be useful to increase sensitivity of exposure assessment.

Effect. It is difficult to monitor the effects of toluene exposure. MRI and BAER evaluations of the brain have some value in determining the neurological damage resulting from long-term exposures to high levels of toluene, but have no known value for determining the effects of low-level and/or short-term exposures.

Methods for Determining Parent Compounds and Degradation Products in Environmental Media. There are methods available for the determination of toluene and its metabolites in environmental samples. Sensitive techniques for air, drinking water, and waste water allow detection of toluene at low levels (Bernado et al. 2009; Campos-Candel et al. 2009; Wan et al. 1998). These techniques are adequate to measure both background toluene levels and the levels of toluene in environmental media that could cause health effects. However, when toluene is present in combination with other volatile materials, interference from the companion volatiles often raises the detection limit and decreases the accuracy and precision of the technique. Improved methods for separation of toluene from other volatiles would be useful.

Research on measuring the levels of metabolites in soil and water would be valuable especially in studying the end products of microbial degradation. Few methods are available for monitoring toluene in foods; reliable methods are needed for evaluating the potential for human exposure that might result from toluene ingestion.

### 7.3.2 Ongoing Studies

The Environmental Health Laboratory Sciences Division of the National Center for Environmental Health, Centers for Disease Control and Prevention, is developing methods for the analysis of toluene and other phenolic compounds in urine. These methods use high-resolution gas chromatography and magnetic sector mass spectrometry, which give detection limits in the low parts per trillion (ppt) range.