# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of toluene is located in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of toluene is located in Table 4-2.

Table 4-1 Chemical Identity of Toluene

Characteristic | Information | Reference
Chemical name | Toluene | HSDB 2010
Synonym(s) | Methylbenzene; phenylmethane; benzene, methyl-; toluol; methylbenzol | Haynes et al. 2013; HSDB 2010
Registered trade name(s) | Methacide; Antisal 1A | HSDB 2010
Chemical formula | C_7_H_8_ | Haynes et al. 2013; HSDB 2010
Chemical structure | [image] | Haynes et al. 2013; HSDB 2010
Identification numbers:
CAS registry | 108-88-3 | Haynes et al. 2013
NIOSH RTECS | XS5250000 | RTECS 2014
EPA hazardous waste | U220 | HSDB 2010
OHM/TADS | 7216928 | NFPA 1994
DOT/UN/NA/IMCO shipping | UN 1294 | HSDB 2010
IMCO | 3.2 | HSDB 2010
HSDB | 131 | HSDB 2010
NCI | CO7272 | HSDB 2010

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; NFPA = National Fire Protection Association; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Toluene

Property | Information | Reference
Molecular weight | 92.13 | Fabri et al. 2012
Color | Colorless | Haynes et al. 2013
Physical state | Liquid | Haynes et al. 2013
Melting point | −94.991°C | Fabri et al. 2012
Boiling point | 110.625°C | Fabri et al. 2012
Density:
at 20°C | 0.8631 g/cm^3^ | Fabri et al. 2012
Vapor density | 3.1 (air=1) | HSDB 2010
Odor | Sweet, pungent, benzene-like odor | HSDB 2010
Odor threshold:
Water | 0.024–0.17 mg/L | WHO 2004
Air | 2.14 ppm (8 mg/m^3^) | HSDB 2010
Solubility:
Water at 25°C | 526 mg/L | HSDB 2010
Organic solvent(s) | Miscible with alcohol, chloroform, ether, acetone, glacial acetic acid, and carbon disulfide | HSDB 2010
Partition coefficients:
Log K_ow_ | 2.73 | HSDB 2010
Log K_oc_ | 1.57–2.25 | HSDB 2010
Vapor pressure at 25°C | 28.4 mm Hg | HSDB 2010
Henry’s law constant: | 6.64x10^−3^ atm-m^3^/mol | HSDB 2010
Autoignition temperature | 480°C (896°F) | HSDB 2010
Flashpoint | 4°C (40°F, closed cup); 16°C (open cup) | HSDB 2010
Flammability limits | 1.1–7.1% | HSDB 2010
Conversion factors ppm (v/v) to mg/m^3^ in air (20°C) | 1 ppm=3.76 mg/m^3^ | HSDB 2010
Explosive limits | 1.27% lower limit | Fabri et al. 2012; HSDB 2010

v/v = volume for volume