# 8 REGULATIONS, ADVISORIES, AND GUIDELINES

MRLs are substance-specific estimates that are intended to serve as screening levels. They are used by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites.

ATSDR has derived an acute-duration inhalation MRL of 1×10^−5^ ppm for TDI. The MRL is based on LOAEL of 0.005 ppm for decreases in lung function in healthy volunteers exposed to TDI for 6 hours (Vandenplas et al. 1999). The LOAEL was adjusted to continuous 24-hour exposure (from 6 hours/day) and divided by a total uncertainty factor of 100 (10 for the use of a LOAEL and 10 for human variability). Since there is uncertainty that the MRL would be protective for continuous exposure for 14 days, it is suggested that measured air concentrations should not exceed the MRL of 1×10^−5^ ppm during a 24-hour period.

ATSDR has derived a chronic-duration inhalation MRL of 3×10^−6^ ppm for TDI. The MRL is based on the mean daily exposure level of 0.0012 ppm, which resulted in decreases in lung function in workers at flexible foam producing facilities (Clark et al. 1998). The adverse effect level of 0.0012 ppm was adjusted for intermittent exposure (8 hours/day, 5 days/week) and divided by a total uncertainty factor of 100 (10 for the use of a LOAEL and 10 for human variability).

EPA (IRIS 2003) has derived a chronic-duration reference concentration (RfC) of 7×10^−5^ mg/m^3^ (1×10^−5^ ppm) based on a NOAEL of 0.0009 ppm and a LOAEL of 0.0019 ppm for decreases in lung function in workers at a TDI manufacturing facility (Diem et al. 1982). The NOAEL was adjusted for intermittent exposure ([10 m^3^/day]/[20 m^3^/day], 5 days/week) and divided by a total uncertainty factor of 30 (3 to account for both extrapolation from a subchronic study and the lack of developmental toxicity data in a second species and 10 for intrahuman variability).

ATSDR has derived a chronic-duration inhalation MRL of 0.001 mg/m^3^ for polymeric MDI. The MRL is based on a BMCL_10_ of 0.48 mg/m^3^ for basal cell hyperplasia in the nasal cavity observed in rats exposed to polymeric MDI for 2 years (Reuzel et al. 1994). The BMCL_10_ was adjusted for intermittent exposure (6 hours/day, 5 days/week) and multiplied by a regional deposited dose ratio for extrathoracic effect (RDDRET) of 0.453 to calculate the human equivalent concentration (BMCL_HEC_). The BMCL_HEC_ of 0.039 mg/m^3^ was divided by a total uncertainty factor of 30 (3 to extrapolate from animals to humans with dosimetric adjustments and 10 for human variability); EPA notes that “the two UFs of 3 each coalesce to a 10, yielding a total UF of 100.”

EPA (IRIS 2002) has derived a chronic-duration RfC of 0.0006 mg/m^3^ based on a BMCL_ADJ_ of 0.14 mg/m^3^ for basal cell hyperplasia in rats exposed to polymeric MDI for 2 years (Reuzel et al. 1994). The BMCL_HEC_ was calculated by multiplying the BMCL_ADJ_ of 0.14 mg/m^3^ by a RDDR_ET_ of 0.453. The BMCL_HEC_ of 0.06 mg/m^3^ was divided by a total uncertainty factor of 100 (10 for intraindividual variation, 3 for the lack of reproductive data, and 3 for “interspecies variation inasmuch as dosimetric adjustments had been made”).

The international and national regulations, advisories, and guidelines regarding TDI and MDI in air, water, and other media are summarized in Table 8-1.

Table 8-1 Regulations, Advisories, and Guidelines Applicable to TDI and MDI

Agency | Description | Information | Reference
[underlined: International]
Guidelines:
IARC | Carcinogenicity classification
| TDI | Group 2B^a^ | IARC 1999b
| 4,4’-MDI | Group 3^b^ | IARC 1999a
WHO | Air quality guidelines | Not listed | WHO 2010
| Drinking water quality guidelines | Not listed | WHO 2017
[underlined: National]
Regulations and guidelines:
a. Air
ACGIH | TLV-TWA^c,d^,^e^
| 2,4-TDI or 2,6-TDI (or as a mixture) | 0.001 ppm^f^ | ACGIH 2016a
| Monomeric 4,4’-MDI | 0.005 ppm | ACGIH 2001
| STEL
| 2,4-TDI or 2,6-TDI (or as a mixture) | 0.005 ppm^f^ | ACGIH 2016a
DOE | PAC-1^g^ | | DOE 2016b
| TDI, mixed isomers | 0.020 ppm
| 2,4-TDI | 0.020 ppm
| 2,6-TDI | 0.020 ppm
| Monomeric 4,4’-MDI | 0.45 mg/m^3^
| Polymeric 4,4’-MDI | 29 mg/m^3^
| PAC-2^g^
| TDI, mixed isomers | 0.083 ppm
| 2,4-TDI | 0.083 ppm
| 2,6-TDI | 0.083 ppm
| Monomeric 4,4’-MDI | 5 mg/m^3^
| Polymeric 4,4’-MDI | 40 mg/m^3^
| PAC-3^g^
| TDI, mixed isomers | 0.51 ppm
| 2,4-TDI | 0.51 ppm
| 2,6-TDI | 0.51 ppm
| Monomeric 4,4’-MDI | 55 mg/m^3^
| Polymeric 4,4’-MDI | 240 mg/m^3^
EPA | 2,4-TDI | | EPA 2016a
| AEGL-1^h^
| 10 minutes | 0.020 ppm
| 30 minutes | 0.020 ppm
| 60 minutes | 0.020 ppm
| 4 hours | 0.010 ppm
| 8 hours | 0.010 ppm
| AEGL-2^h^
| 10 minutes | 0.24 ppm
| 30 minutes | 0.17 ppm
| 60 minutes | 0.083 ppm
| 4 hours | 0.021 ppm
| 8 hours | 0.021 ppm
| AEGL-3^h^
| 10 minutes | 0.65 ppm
| 30 minutes | 0.65 ppm
| 60 minutes | 0.51 ppm
| 4 hours | 0.32 ppm
| 8 hours | 0.16 ppm
| 2,6-TDI
| AEGL-1^h^
| 10 minutes | 0.020 ppm
| 30 minutes | 0.020 ppm
| 60 minutes | 0.020 ppm
| 4 hours | 0.010 ppm
| 8 hours | 0.010 ppm
| AEGL-2^h^
| 10 minutes | 0.24 ppm
| 30 minutes | 0.17 ppm
| 60 minutes | 0.083 ppm
| 4 hours | 0.021 ppm
| 8 hours | 0.021 ppm
| AEGL-3 ^h^
| 10 minutes | 0.65 ppm
| 30 minutes | 0.65 ppm
| 60 minutes | 0.51 ppm
| 4 hours | 0.32 ppm
| 8 hours | 0.16 ppm
| Hazardous air pollutant | | EPA 2016c 42 USC
| 2,4-TDI | Yes | 7412
| Monomeric 4,4’-MDI | Yes
| NAAQS | Not listed | EPA 2018b
NIOSH | REL | | NIOSH 2016a, 2016b
| 2,4-TDI | Potential occupational carcinogens | NIOSH 2016a, 2016b
| Monomeric 4,4’-MDI | 0.05 mg/m^3^
| Ceiling limit (10-minute)
| Monomeric 4,4’-MDI | 0.2 mg/m^3^
| IDLH
| 2,4-TDI | 2.5 ppm
| Monomeric 4,4’-MDI | 75 mg/m^3^
OSHA | Ceiling limit (15-minute TWA) for general industry | | OSHA 2017b 29 CFR 1910.1000, Table Z-2
| 2,4-TDI | 0.02 ppm | OSHA 2017b 29 CFR 1910.1000, Table Z-2
| Monomeric 4,4’-MDI | 0.02 ppm
| Highly hazardous chemicals | Not listed | OSHA 2017a 29 CFR 1910.119, Appendix A
b. Water
EPA | Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act | Not listed | EPA 2017b; 40 CFR 116.4
| Drinking water contaminant candidate list | | EPA 2016b; 81 FR 81099
| TDI | Yes
| Drinking water standards and health advisories | Not listed | EPA 2012
| National primary drinking water standards | Not listed | EPA 2009b
| National recommended water quality criteria: human health for the consumption of (at 10^−4^ risk) | Not listed | EPA 2018c
| Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act | Not listed | EPA 2017d; 40 CFR 117.3
c. Food
FDA | Bottled water | Not listed | FDA 2017 21 CFR 165.110
| EAFUS^i^ | Not listed | FDA 2013
d. Other
ACGIH | Carcinogenicity classification | | ACGIH 2016a
| 2,4-TDI or 2,6-TDI (or as a mixture) | A3^j^
EPA | Carcinogenicity classification | | IRIS 2002, 2003
| TDI (toluene 2,4- (2,6-) diisocyanate) | No data
| MDI (monomeric MD) and polymeric MDI) | Group D^k^
| RfC
| 2,4-/2,6-TDI | 7×10^−5^ mg/m^3^
| MDI (monomeric MDI and polymeric MDI) | 6×10^−4^ mg/m^3^
| RfD
| 2,4-/2,4-TDI (toluene 2,4- (2,6-) diisocyanate) | Not listed
| MDI (monomeric MDI and polymeric MDI) | Not listed
| Identification and listing of hazardous waste | | EPA 2017c 40 CFR 261,
| TDI (toluene 2,4- (2,6-) diisocyanate) | U223 | Appendix VIII
| Master Testing List | | EPA 1996
| Monomeric 4,4’-MDI | Yes
| Polymethylene polyphenyl isocyanate | Yes
| Polymeric 4,4’-MDI | Yes
| RCRA waste minimization PBT priority chemical list | Not listed | EPA 1998b 63 FR 60332
| Standards for owners and operators of hazardous waste TSD facilities; groundwater monitoring list; Superfund, emergency planning, and community right-to-know | Not listed | EPA 2017e 40 CFR 264, Appendix IX
| Designated CERCLA hazardous substance and reportable quantity | | EPA 2017f 40 CFR 302.4
| TDI (toluene 2,4- (2,6-) diisocyanate)^l^ | 100 pounds
| 2,4-TDI’ | 100 pounds
| 2,6-TDI’ | 100 pounds
| Monomeric 4,4’-MDI^m^ | 5,000 pounds
| Effective date of toxic chemical release reporting | | EPA 2017g 40 CFR 372.65
| TDI (toluene 2,4- (2,6-) diisocyanate) | 01/01/1990
| 2,4-TDI | 01/01/1987
| 2,6-TDI | 01/01/1987
| Monomeric 4,4’-MDI | 01/01/1987
| Diisocyanates category (including MDI and polymeric MDI) | 01/01/1995
| Extremely hazardous substances and its threshold planning quantity | | EPA 2017h 40 CFR 355,
| 2,4-TDI | 500 pounds | Appendix A
| 2,6-TDI | 100 pounds
| TSCA chemical lists and reporting periods | | EPA 2017i 40 CFR 712.30
| Monomeric 4,4’-MDI
| Effective date | 10/29/1990
| Reporting date | 12/27/1990
| Polymeric 4,4’-DMDI
| Effective date | 10/29/1990
| Reporting date | 12/27/1990
| TSCA health and safety data reporting | | EPA 2017j 40 CFR 716.120
| TDI (2,4 and 2,6 mixed isomers); 2,4-TDI; monomeric 4,4’-MDI; polymeric 4,4’-MDI
| Effective date | 06/01/1987
| Reporting date | 06/01/1997
| 2,6-TDI
| Effective date | 06/01/1987
| Reporting date | 12/19/1995
NTP | Carcinogenicity classification | | NTP 2016
| TDI | Reasonably anticipated to be a human carcinogen

a Group 2B: possibly carcinogenic to humans.

b Group 3: not classifiable as to its carcinogenicity to humans.

c Skin notation: refers to potential significant contribution to the overall exposure by the cutaneous route (ACGIH 2016b).

d Dermal sensitization notation: refers to potential for agent to produce dermal sensitization (ACGIH 2016b).

e Respiratory sensitization notation: refers to potential for agent to produce respiratory sensitization (ACGIH 2016b).

f Inhalable fraction and vapor: material exerts sufficient vapor pressure such that it may be present in both particle and vapor phases, with each contributing a significant portion of the dose at the TLV-TWA concentration (ACGIH 2016b).

g Definitions of PAC terminology are available from DOE (2016a).

h AEGL-1 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience notable discomfort, irritation, or certain asymptomatic nonsensory effects. However, the effects are not disabling and are transient and reversible upon cessation of exposure. AEGL-2 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience irreversible or other serious, long-lasting adverse health effects or an impaired ability to escape. AEGL-3 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience life-threatening health effects or death (EPA 2018a).

i The EAFUS list of substances contains ingredients added directly to food that FDA has either approved as food additives or listed or affirmed as GRAS.

j A3: confirmed animal carcinogen with unknown relevance to humans.

k Group D: not classifiable as to human carcinogenicity.

l Designated CERCLA hazardous substance and reportable quantity pursuant to Section 112 of the Clean Air Act and Section 3001 of RCRA.

m Designated CERCLA hazardous substance and reportable quantity pursuant to Section 112 of the Clean Air Act.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; CERCLA = Comprehensive Environmental Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FR = Federal Register; GRAS = generally recognized as safe; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; MDI = methylenediphenyl diisocyanate; NAAQS = National Ambient Air Quality Standards; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PBT = persistent, bioaccumulative, and toxic; RCRA = Resource Conservation and Recovery Act; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; SIDS = Screening Information Data Set; STEL = short-term exposure limit; TDI = toluene diisocyanate; TLV = threshold limit values; TSCA = Toxic Substances Control Act; TSD = treatment, storage, and disposal; TWA = time-weighted average; USC = United States Code; WHO = World Health Organization