# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of TDI and MDI is provided in Table 4-1.

TDI and MDI have widespread commercial use due to their reactivity and versatility. TDI and MDI and their related polyisocyanates make up >90% of the commercial market (EPA 2011a). Commercial-grade TDI is made up of an 80:20 mixture of isomers 2,4- and 2,6-TDI and represents >95% of TDI industrial use (NIOSH 1989).

Commercial-grade MDI consists of several isomers, including 4,4’-, 2,4’-, and 2,2’-MDI, as well as oligomers and polymeric compounds. The principal commercial product of MDI is made up of a mixture of all of these components, with a typical composition in the range of 40–50% 4,4’-MDI, 2.5–4.0% 2,4’-MDI, and 0.1–0.2% 2,2’-MDI; the remainder is oligomers. 4,4’-MDI is the most commercially common isomer and is referred to as pure MDI (IARC 1999a).

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of TDI and MDI is provided in Table 4-2.

Table 4-1 Chemical Identity of Toluene Diisocyanate and Methylenediphenyl Diisocyanate^a^

Characteristic | Methylenediphenyl diisocyanate | Toluene diisocyanate
Chemical name | Benzene, 1,1 ’-methylenebis(4-isocyanato-) | Benzene, 1,3-diisocyanato- methyl-
Synonyms(s) | 4,4’-Methylenedi(phenyl isocyanate);; 4,4’-methylenebis(phenyl isocyanate);; 4,4’-methylenediphenyl diisocyanate;; bis(4-isocyanatophenyl)methane;; isocyanic acid, methylenedi-p-phenylene ester; MDI | Diisocyanatotoluene;; isocyanic acid, methylphenylene ester;; methylphenylene isocyanate; TDI
Registered trade name(s) | Caradate 30; Desmodur 44; Hylene M;; Isonate M; Nacconate | TDI 80/20; Mondur TD; Hylene; T; Rubinate TDI; Niax TDI
Chemical formula | C_15_H_10_N_2_O_2_ | C_9_H_6_N_2_O_2_
Chemical structure | [image] | [image]
Identification numbers:
CAS registry | 101-68-8; 9016-87-9 (polymeric MDI) | 26471-62-5 (mixture of 2,4-TDI and 2,6-TDI)
NIOSH RTECS | NQ9350000^b^ | NQ9490000^e^
EPA hazardous waste | No data | U223
OHM/TADS | No data | No data
DOT/UN/NA/IMCO | UN 2489^c^ | UN 2078
shipping | IMO 6.1^d^ | IMO 6.1
HSDB | 2630 | 6003
NCI | C50668 | No data
Characteristic | 2,4-Toluene diisocyanate | 2,6-Toluene diisocyanate
Chemical name | Benzene, 2,4-diisocyanato-1-methyl | Benzene, 1,3-diisocyanato- 2-methyl
Synonyms(s) | 2.4- Diisocyanatotoluene; isocyanic acid,; 4-methyl-m-phenylene ester;4-methyl-; phenylene diisocyanate; toluene-; 2,4- diisocyanate; 2,4-TDI | 2.6- Diisocyanatotoluene;; 2,6- diisocyanto-1-methylbenzene;; 2-methyl-phenylene diisocyanate;; toluene-2,6-diisocyanate; 2,6-TDI
Registered trade name(s) | Hylene T; Mondur TDS | Hylene T; Mondur TDS
Chemical formula | C_9_H_6_N_2_O_2_ | C_9_H_6_N_2_O_2_
Chemical structure | [image] | [image]
Identification numbers:
CAS registry | 584-84-9 | 91-08-7
NIOSH RTECS | CZ6300000^f^ | CZ6310000^g^
EPA hazardous waste | U223 | U223
OHM/TADS | No data | No data
DOT/UN/NA/IMCO | UN 2206/2207/2478/3080^d^ | UN 2207^d^
shipping | IMO 6.1 | IMO 6.1
HSDB | 874 | 5272
NCI | C50533 | No data

a All information obtained from HSDB (2012), unless otherwise noted.

b RTECS 2009a

c ChemSpider 2013

d Lewis 2004

e NIOSH 1989

f RTECS 2009b

g RTECS 2009c

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/Intergovernmental Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS=Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Toluene Diisocyanate and Methylenediphenyl Diisocyanate^a^

Property | Methylenediphenyl diisocyanate | Toluene diisocyanate
Molecular weight | 250.252 | 174.16
Color | Light-yellow | Clear, colorless to pale yellow
Physical state | Solid/crystals | Liquid
Melting point | 37°C | 11–14°C
Boiling point | 196°C (at 5 mm Hg) | 250°C
Density:
at 25°C | No data | 1.22 g/mL
at 70°C | 1.197 g/cm^3^ | No data
Odor | Odorless | Pungent
Odor threshold:
Water | Not applicable^b^ | Not applicable^b^
Air | No data | 360–920 μg/m^3^
Solubility:
Water at 25°C | Not applicable^b^ | Not applicable^b^
Organic solvents | Soluble in acetone, benzene, kerosene, and nitrobenzene | Miscible with alcohol, ether, acetone, carbon tetrachloride, benzene, and kerosene
Partition coefficients:
Log K_ow_ | Not applicable^b^ | Not applicable^b^
Log K_oc_ | Not applicable^b^ | Not applicable^b^
Vapor pressure at 25°C | 5.1×10^−6^ mm Hg | 2.30×10^−2^ mm Hg
Henry’s law constant at 25°C | Not applicable^b^ | Not applicable^b^
Autoignition temperature | No data | No data
Flashpoint | 202°C (open cup) | 132°C (closed cup)
Flammability limits | Flammable^c^ | 0.9–9.5 volume %
Conversion factors | 1 ppm=10.24 mg/m^3^ | No data
Explosive limits | No data | Explosive (vapor)
Property | 2,4-Toluene diisocyanate | 2,6-Toluene diisocyanate
Molecular weight | 174.16 | 174.16
Color | Colorless to pale yellow | Colorless to pale yellow
Physical state | Liquid | Liquid
Melting point | 20.5°C | 18.3°C
Boiling point | 251°C | 129–133°C (at 18 mm Hg)
Density:
at 20°C/4°C | 1.2244 | No data
at 25°C | No data | 1.22
Odor | Sharp, pungent | Pungent
Odor threshold:
Water | Not applicable^b^ | Not applicable^b^
Air | 0.4–2.14 ppm | No data
Solubility:
Water at 25°C | Not applicable^b^ | Not applicable^b^
Organic solvents | Miscible with alcohol (decomposition), ether, acetone, benzene, carbon tetrachloride, chlorobenzene, diglycol monomethyl ether, kerosene, and olive oil | Soluble in acetone and benzene
Partition coefficients:
Log K_ow_ | Not applicable^b^ | Not applicable^b^
Log K_oc_ | Not applicable^b^ | Not applicable^b^
Vapor pressure at 25°C | 8.0×10^−3^ mm Hg (20°C) | 2.09×10^−2^ mm Hg
Henry’s law constant at 25°C | Not applicable^b^ | Not applicable^b^
Autoignition temperature | 620°C | No data
Flashpoint | 132°C (open cup)^c^ | No data
Flammability limits | 0.9–9.5 volume % | Flammable
Conversion factors | No data | 1 mg/m^3^=0.14 ppm
Explosive limits | Explosive (vapor) | No data

a All information obtained from HSDB (2012), unless otherwise noted.

b Diisocyanates hydrolyze rapidly in water; therefore, these end points are not applicable.

c Lewis 2004