# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99-499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-57, Atlanta, Georgia 30329-4027.

## Toluene diisocyanate Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Toluene diisocyanate
CAS Number: | 26471-62-5
Date: | June 2018
Profile Status: | Final
Route: | [X] Inhalation [ ] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 1
Species: | Humans

[underlined: Minimal Risk Level]: 1×10^−5^ [ ] mg/kg/day [X] ppm

[underlined: Reference]: Vandenplas O, Delwiche J-P, Staquet P, et al. 1999. Pulmonary effects of short-term exposure to low levels of toluene diisocyanate in asymptomatic subjects. Eur Respir J 13:1144–1150.

[underlined: Experimental design]: In this single-blind crossover design study, 17 volunteers (8 male, 9 females) were exposed to ambient air or 0.005 ppm TDI for 6 hours followed by a 20-minute exposure to 0.020 ppm TDI. Pulmonary function testing was conducted prior to exposure and every hour during the 6-hour exposure and at the end of the 20-minute exposure to 0.020 ppm or air. Bronchial lavage (BL) and bronchoalveolar lavage (BAL) were performed 1 hour after the end of the exposure.

[underlined: Effect noted in study and corresponding doses]: None of the subjects reported respiratory symptoms in response to the exposure. TDI exposure was associated with a slight, but significant, decrease in specific airway conductance (sGaw) and maximal expiratory flow at 25% of forced vital capacity (MEF_25%_). No significant alterations in the volume of fluid recovered or total and differential cell counts were observed in the BL and BAL after TDI exposure, as compared to air exposure. Exposure to TDI was associated with a decrease in the proportion of CD19 cells in the BL and BAL, although there was no difference in the absolute number of cells. A slight but statistically significant increase in BAL albumin levels and BL α-2-macroglobulin levels were observed.

[underlined: Dose and end point used for MRL derivation]: LOAEL of 0.005 ppm for decreased lung function

[ ] NOAEL [X ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 10 for use of a LOAEL
- [ ] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Yes. The LOAEL of 0.005 ppm was adjusted for intermittent exposure:

0.005 ppm × 6 hours/24 hours = 0.00125 ppm

[underlined: Other additional studies or pertinent information that lend support to this MRL]: In another acute-duration human study, no alterations in specific air way resistance were observed in healthy or asthmatic subjects exposed to 0.02 ppm TDI for 20 minutes (Chester et al. 1979). Acute-duration animal inhalation studies have reported rhinitis, lung damage, and airway hyperresponsiveness. The severity of rhinitis was concentration-related; moderate rhinitis was observed in mice exposed to 0.07 ppm 6 hours/day for 4 days (Zissu 1995), moderate-to-severe rhinitis was observed in mice exposed to 0.4 ppm 6 hours/day for 5 days (Buckley et al. 1984), and severe nasal lesions were observed in mice exposed to 1 ppm 6 hours/day for 3 days (Arts et al. 2008). Interstitial inflammation, pleural thickening, and goblet cell hyperplasia were observed in the lungs of guinea pigs exposed to 1.4 ppm TDI 3 hours/day for 3 days (Wong et al. 1985). Airway hyperresponsiveness to methacholine or acetylcholine was also observed in guinea pigs and mice exposed to ≥0.01 ppm (Gagnaire et al. 1996; Gordon et al. 1985; Marek et al. 1999); a NOAEL of 0.005 ppm for airway hyperresponsiveness was identified in guinea pigs exposed to TDI 6 hours/day for 5 days (Marek et al. 1999). An increase in the incidence of litters with poorly ossified cervical centrum was observed in the offspring of rats exposed to 0.5 ppm commercial-grade TDI 6 hours/day on GDs 6–15 (Tyl et al. 1999a); this concentration was also associated with maternal toxicity including a marked decrease in body weight gain and signs of nasal irritation and audible respiration.

Support for basing the MRL on a single exposure study comes from chronic occupational exposure studies. The lowest LOAEL values identified in longitudinal studies of workers exposed to TDI were 0.0012 and 0.0019 ppm (Clark et al. 1998; Diem et al. 1982); the effects observed at these concentrations included decreases in lung function (FEV_1_ and/or FVC). These LOAELs are roughly 2–4 times lower than the LOAEL from the Vandenplas et al. (1999) study. However, since there is uncertainty that the MRL would be protective for continuous exposure for 14 days, it is suggested that measured air concentrations should not exceed the MRL of 1×10^−5^ ppm during a 24-hour period.

[underlined: Agency Contact (Chemical Manager)]: Malcolm Williams

## Toluene diisocyanate Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Toluene diisocyanate
CAS Number: | 26471-62-5
Date: | June 2018
Profile Status: | Final
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 26
Species: | Humans

[underlined: Minimal Risk Level]: 3×10^−6^ [ ] mg/kg/day [X] ppm

[underlined: Reference]: Clark RL, Bugler J, McDermott M, et al. 1998. An epidemiology study of lung function changes of toluene diisocyanate foam workers in the United Kingdom. Int Arch Occup Environ Health 71:169–179.

[underlined: Experimental design]: A group of 780 (649 males, 131 females) workers employed at 12 flexible foam-producing factories in the United Kingdom were examined over a 5-year period; all subjects had taken at least three pulmonary function tests over a period of at least 1 year. Workers were divided into three groups: (1) the exposed group (472 males and 49 females), which consisted of workers employed in the manufacture of polyurethane foam or were handling freshly manufactured products still emitting measurable quantities of TDI; (2) the handling group (80 males and 43 females), consisting of workers handling cold polyurethane products from which TDI emissions could not usually be detected; and (3) the low-exposure group (97 males and 39 females), consisting of shop floor and office workers (control group). The average time in the study was 4.3 years. Workers completed respiratory questionnaires at the start of the study and at the end (or when they left the study); pulmonary function testing was conducted annually at the same time of day, same day of the week, and same month of the year. The mean daily exposure to TDI was 0.0096-hours ppm (0.0012 ppm 8-hour TWA). The investigators noted that although 4.7% of the measurements exceeded the 8-hour TWA concentration limit of 0.0058 ppm, most of the subjects were exposed to <0.00125 ppm. Additionally, 19% of the samples in the exposed group exceeded the 15-minute short-term limit of 0.02 ppm.

[underlined: Effect noted in study and corresponding doses]: Significant increases in the prevalence of wheezing were observed in the handling and exposed groups; however, there were only small differences between the two groups. Longitudinal analysis did not find a significant exposure-related effect on lung function. Twenty-four cases of respiratory sensitization were identified; the FEV_1_ decline was greater in these subjects than those not sensitized. A study of 157 naïve subjects (workers who entered the study after the first longitudinal measurements were made) showed no difference in FEV_1_ decline as compared to exposed non-naïves. However, longitudinal regression showed the mean daily exposure to be significant for annual changes in FEV_1_ and FVC. These declines were more rapid in the early years of employment, frequently during the first few months of employment. Clark et al. (1998) suggested that the decline in lung function may have been due to respiratory irritation.

[underlined: Dose and end point used for MRL derivation]: The MRL was based on the mean daily exposure level for the exposed group of 0.0012 ppm that was associated with a significant decrease in lung function; this concentration was treated as an adverse effect level for the purposes of deriving the MRL.

[ ] NOAEL [X] Adverse Effect Level (AEL)

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 10 for use of a AELE
- [ ] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Yes. The AEL of 0.0012 ppm was adjusted for intermittent exposure:

0.0012 ppm × 8 hours/24 hours × 5 days/7 days = 0.00029 ppm

[underlined: Other additional studies or pertinent information that lend support to this MRL]: The toxicity of TDI has been examined in a large number of occupational exposure studies that identify the respiratory tract as the primary target of toxicity; they are supported by a number of animal studies. In humans, the primary respiratory effects are occupational asthma, asthma-like symptoms (e.g., wheezing, dyspnea, chest tightness), and decreases in lung function. The occupational asthma and possibly the asthma-like symptoms are observed in individuals sensitized to TDI. Although the prevalence of sensitization is not known, it is likely <10% based on older literature when the occupational exposures were higher and may now be as low as <1% since the occupational exposure limit was lowered to 0.005 ppm (Ott et al. 2003). Exposure to very low concentrations of TDI can elicit an asthma response in sensitized individuals; in non-sensitized individuals, this concentration would be non-irritating. Although there is some indication of an improvement in asthma symptoms after discontinuing TDI exposure, a fair percentage of sensitized workers still report symptoms >10 years after exposure termination (Mapp et al. 1988; Moller et al. 1986; Moscato et al. 1991; Padoan et al. 2003; Paggiaro et al. 1984).

The primary effect observed in non-sensitized workers is a decline in lung function (Adams 1975; Bodner et al. 2001; Butcher et al. 1977; Clark et al. 1998, 2003; Diem et al. 1982; Jones et al. 1992; Omae et al. 1992; Ott et al. 2000; Peters et al. 1970; Wegman et al. 1977, 1982). Based on the results of the Clark et al. (1998) study and a prospective longitudinal study by Diem et al. (1982), it appears that the greatest declines in lung function occur during the first couple of years of exposure to TDI; thereafter, continued exposure to lower TDI levels does not result in further annual declines in lung function.

Chronic exposure to TDI resulted in chronic or necrotic rhinitis with epithelial atrophy and mucous and squamous metaplasia in mice exposed to 0.05 ppm TDI 6 hours/day, 5 days/week for 2 years (Loeser 1983). In the lungs, interstitial pneumonitis and catarrhal bronchitis were observed.

[underlined: Agency Contact (Chemical Manager)]: Malcolm Williams

## Polymeric methylenediphenyl diisocyanate Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Polymeric methylenediphenyl diisocyanate
CAS Number: | 9016-87-9
Date: | June 2018
Profile Status: | Final
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 8
Species: | Rat

[underlined: Minimal Risk Level]: 0.001 [ ] mg/kg/day [X] mg/m^3^

[underlined: Reference]: Reuzel PGJ, Arts JHE, Lomax LG, et al. 1994. Chronic inhalation toxicity and carcinogenicity study of respirable polymeric methylene diphenyl diisocyanate (polymeric MDI) aerosol in rats. Fundam Appl Toxicol 22:195–210.

[underlined: Experimental design]: Groups of 70 male and 70 female Wistar rats were exposed to 0, 0.2, 1.0, or 6.0 mg/m^3^ polymeric MDI for 6 hours/day, 5 days/week for 2 years; after 1 year of exposure, 10 rats/sex/group were sacrificed for interim evaluation. The test substance contained 44.8–50.2% monomeric MDI. The mass median aerodynamic diameter (MMAD) particle sizes (and geometric standard deviation [GSD]) were 0.68 (2.93), 0.70 (2.46), and 0.74 (2.31) µm, respectively. The following parameters were used to evaluate toxicity in the rats exposed for 1 year: clinical signs, body weight (weekly for the first 13 weeks and monthly thereafter), hematology (red and white blood cell counts, hemoglobin, packed cell volume, differential white blood cell count, prothrombin time), urinary parameters (volume, density, pH, protein, occult blood, glucose, ketones), clinical chemistry (albumin, alkaline phosphatase, alanine aminotransferase, aspartate aminotransferase, urea nitrogen, total protein, creatinine, electrolytes, inorganic phosphate, cholesterol, triglycerides and glucose), and histopathological examination of major tissues and organs. Histopathological examination of major tissues and organs was also conducted in the control and 6.0 mg/m^3^ after 2 years of exposure and the nose, lungs, and mediastinal lymph nodes were examined in the 0.2 and 1.0 mg/m^3^ group after 2 years of exposure.

[underlined: Effect noted in study and corresponding doses]: Sniffing (no additional information provided) was observed in the 6.0 mg/m^3^ group after removal from the exposure chamber during months 5 and 6. No treatment-related increases in mortality were observed, and there were no alterations in body weight gain. No alterations in hematological, clinical chemistry, or urinalysis parameters were observed. Significant increases in absolute and relative lung weights were observed in the 6.0 mg/m^3^ group after 1 and 2 years of exposure. In the rats sacrificed after 1 year of exposure, histological alterations were observed in the nasal cavity, lungs, and mediastinal lymph nodes. In the lungs, the lesions consisted of pneumonitis in the 1.0 and 6.0 mg/m^3^ males, alveolar duct epithelialization in males at 6.0 mg/m^3^ and females at 1.0 and 6.0 mg/m^3^, and minimal to moderate localized fibrosis and accumulation of macrophages with yellow pigment in the 6.0 mg/m^3^ males and females. An accumulation of macrophages with yellow pigment was also observed in the lymph nodes of male and female rats exposed to 1.0 or 6.0 mg/m^3^. In the nasal cavity, minimal to moderate olfactory epithelial disarrangement was observed in males at 6.0 mg/m^3^. Alterations were also observed in the lungs, mediastinal lymph nodes, and nasal cavity after 2 years of exposure. Lung effects included adenoma in males exposed to 6.0 mg/m^3^, accumulation of macrophages with yellow pigment in males and females at 1.0 and 6.0 mg/m^3^, localized fibrosis in males at 1.0 and 6.0 mg/m^3^ and females at 6.0 mg/m^3^, alveolar duct epithelialization in males and females at 1.0 and 6.0 mg/^3^, and localized alveolar bronchiolization in males and females at 6.0 mg/m^3^. An accumulation of macrophages with yellow pigment was observed in the mediastinal lymph nodes in males at 1.0 and 6.0 mg/m^3^ and females at 6.0 mg/m^3^. Nasal effects included basal cell hyperplasia and Bowman’s gland hyperplasia in males at 1.0 and 6.0 mg/m^3^, basal cell hyperplasia in females at 6.0 mg/m^3^, and minimal to severe olfactory epithelial degeneration in males and females at 6.0 mg/m^3^. No significant increases in tumors were observed.

[underlined: Dose and end point used for MRL derivation]: BMCL_10_ of 0.48 mg/m^3^ for basal cell hyperplasia

[ ] NOAEL [ ] LOAEL [X] BMCL

The incidence data (Table A-1) for basal cell hyperplasia in the nasal cavity, Bowman’s duct hyperplasia in the nasal cavity, and lung fibrosis were fit to all available dichotomous models in EPA’s Benchmark Dose Software (BMDS, version 2.4.0) using the extra risk option. Adequate model fit was judged by three criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined benchmark dose response (BMR). Among all of the models providing adequate fit to the data, the lowest BMCL (95% lower confidence limit on the benchmark concentration) was selected as the point of departure when the difference between the BMCLs estimated from these models were more 3-fold; otherwise, the BMCL from the model with the lowest Akaike’s Information Criterion (AIC) was chosen. For all three lesion types, a BMR of 10% was used. The model predictions for basal cell hyperplasia are presented in Table A-2. The incidence data for Bowman’s gland hyperplasia did not fit any of the available dichotomous models. The model predictions for the incidence of lung fibrosis are presented in Table A-3.

Table A-1 Incidence of Nasal and Pulmonary Lesions in Male Rats Exposed to Polymeric Methylenediphenyl Diisocyanate

| Exposure concentration (mg/m^3^)
| 0 | 0.2 | 1.0 | 6.0
Basal cell hyperplasia | 14/60 | 13/60 | 26/60 | 32/60
Bowman’s gland hyperplasia | 0/60 | 2/60 | 9/60 | 17/60
Lung fibrosis | 1/60 | 0/60 | 9/60 | 44/60

Source: Reuzel et al. 1994

Table A-2 Model Predictions for Incidence of Basal Cell Hyperplasia in Male Rats Exposed to Polymeric Methylenediphenyl Diisocyanate (mg/m^3^)

Model | DF | χ^2^ | χ^2^ Goodness of fit p-value^a^ | Scaled residuals^b^ | | | AIC | BMC_10_ (mg/m^3^) | BMCL_10_ (mg/m^3^)
Model | DF | χ^2^ | χ^2^ Goodness of fit p-value^a^ | Dose below BMC | Dose above BMC | Overall largest | AIC | BMC_10_ (mg/m^3^) | BMCL_10_ (mg/m^3^)
Gamma^c^ | 2 | 4.8 | 0.09 | 1.87 | −0.45 | 1.87 | 301.60 | ND | ND
Logistic | 2 | 5.76 | 0.06 | 2.01 | −0.28 | 2.01 | 302.55 | ND | ND
LogLogistic ^d^ ^,^ ^f^ | 2 | 3.96 | 0.14 | 1.67 | −0.62 | 1.67 | 300.81 | 0.87 | 0.48
LogProbit^d^ | 2 | 7.56 | 0.02 | 2.30 | −0.28 | 2.30 | 304.25 | ND | ND
Multistage (1 degree)^e^ | 2 | 4.8 | 0.09 | 1.87 | −0.45 | 1.87 | 301.60 | ND | ND
Multistage (2 degree)^e^ | 2 | 4.8 | 0.09 | 1.87 | −0.45 | 1.87 | 301.60 | ND | ND
Multistage (3-degree)^e^ | 2 | 4.8 | 0.09 | 1.87 | −0.45 | 1.87 | 301.60 | ND | ND
Probit | 2 | 5.7 | 0.06 | 2.00 | −0.29 | 2.00 | 302.49 | ND | ND
Weibull^c^ | 2 | 4.8 | 0.09 | 1.87 | −0.45 | 1.87 | 301.60 | ND | ND
Quantal-Linear | 2 | 4.8 | 0.09 | 1.87 | −0.45 | 1.87 | 301.60 | ND | ND

AIC = Akaike Information Criterion; BMC = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., _10_ = exposure concentration associated with 10% extra risk); DF = degrees of freedom; ND = not determined, model does not provide adequate fit to the data

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b Scaled residuals at doses immediately below and above the BMD; also the largest residual at any dose.

c Power restricted to ≥1.

d Slope restricted to ≥1.

e Betas restricted to ≥0.

f Selected model. The only model that was fit to the data was the LogLogistic model (all other models had a p-value <0.1).

Table A-3 Model Predictions for Incidence of Lung Fibrosis in Male Rats Exposed to Methylenediphenyl Diisocyanate (mg/m^3^)

Model | DF | χ^2^ | χ^2^ Goodness of fit p-value^a^ | Scaled residuals^b^ | | | AIC | BMC_10_ (mg/m^3^) | BMCL_10_ (mg/m^3^)
Model | DF | χ^2^ | χ^2^ Goodness of fit p-value^a^ | Dose below BMC | Dose above BMC | Overall largest | AIC | BMC_10_ (mg/m^3^) | BMCL_10_ (mg/m^3^)
Gamma^c^ | 1 | 2.04 | 0.15 | 0.63 | −0.16 | −1.12 | 139.67 | 0.90 | 0.57
Logistic | 2 | 8.46 | 0.01 | 2.23 | −0.20 | 2.23 | 144.69 | ND | ND
LogLogistic^d,f^ | 1 | 1.73 | 0.19 | 0.43 | −0.15 | −1.06 | 139.22 | 0.87 | 0.57
LogProbit ^d^ | 2 | 1.3 | 0.52 | 0.35 | −0.20 | −0.84 | 136.40 | 0.87 | 0.70
Multistage (1-degree)^e^ | 2 | 4.42 | 0.11 | −0.65 | 0.73 | −1.69 | 141.53 | 0.54 | 0.43
Multistage (2-degree)^e^ | 1 | 2.64 | 0.10 | 0.67 | −0.07 | −1.36 | 140.83 | 0.89 | 0.51
Multistage (3-degree)^e^ | 1 | 2.64 | 0.10 | 0.67 | −0.07 | −1.36 | 140.83 | 0.89 | 0.51
Probit | 2 | 7.46 | 0.02 | 2.11 | −0.23 | 2.11 | 143.53 | ND | ND
Weibullc | 1 | 2.2 | 0.14 | 0.64 | −0.12 | −1.19 | 139.99 | 0.90 | 0.55
Quantal-Linear | 2 | 4.42 | 0.11 | −0.65 | 0.73 | −1.69 | 141.53 | 0.54 | 0.43

AIC = Akaike Information Criterion; BMC = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., _10_ = exposure concentration associated with 10% extra risk); DF = degrees of freedom; ND = not determined, model does not provide adequate fit to the data

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b Scaled residuals at doses immediately below and above the BMD; also the largest residual at any dose.

c Power restricted to ≥1.

d Slope restricted to ≥1.

e Betas restricted to ≥0.

f Selected model. All models, except for the Logistic and the Probit (p<0.1) were fit to the data. BMDLs for models providing adequate fit were sufficiently close (differed by <2–3-fold), so the model with the lowest AIC was selected (LogLogistic Model).

Figure A-1 Fit of LogLogistic Model to Data on Incidence of Basal Cell Hyperplasia in Male Rats Exposed to Polymeric Methylenediphenyl Diisocyanate (mg/m^3^)

Figure A-2 Fit of LogLogistic Model to Data on for Incidence of Lung Fibrosis in Male Rats Exposed to Polymeric Methylenediphenyl Diisocyanate (mg/m^3^)

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 3 for extrapolation from animals to humans with dosimetric adjustment
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Yes.

The BMCL_ADJ_ of 0.086 mg/m^3^ was converted to a human equivalent concentration (BMCL_HEC_) of 0.039 mg/m^3^ using the RDDR program (EPA 1990) as follows:

- BMCL_HEC_ = BMCL_ADJ_ × RDDR
- BMCL_HEC_ = 0.086 mg /m^3^ × 0.453
- BMCL_HEC_ = 0.039 mg/m^3^

where:

- RDDR is a multiplicative factor used to adjust an observed inhalation particulate exposure concentration of an animal to the predicted inhalation particulate exposure concentration for a human. The RDDR multiplier of 0.453 for the extrathoracic region tract was determined using the default chronic body weight of 462 g for male Wistar rats (EPA 1988) and a particle size MMAD±GSD of 0.68±2.93 µm reported in the Reuzel et al. (1994) study.

[underlined: Was a conversion used from intermittent to continuous exposure]? Yes.

A BMCL_ADJ_ was calculated by adjusting the BMCL_10_ of 0.48 mg/m^3^ for intermittent exposure:

0.048 mg/m^3^ x 6 hours / 24 hours x 5 days / 7 days = 0.086 mg/m^3^

[underlined: Other additional studies or pertinent information that lend support to this MRL]: The respiratory tract is the primary target of MDI toxicity in humans and animals. Occupational asthma, asthma-like symptoms, and decreases in lung function have been reported in occupational exposure studies (Hur et al. 2008; Liss et al. 1988; Musk et al. 1982; Sulotto et al. 1990; Wang and Petsonk 2004; Woellner et al. 1997; Zamit-Tabona et al. 1983). The occupational asthma and asthma-like symptoms result from sensitization to MDI following a brief exposure to very high concentrations or prolonged exposure to lower concentrations; the prevalence of MDI-sensitization is believed to be low. Liss et al. (1988) reported significant declines in FEV_1_ levels when pre-shift levels were compared to post-shift levels; however, the study did not provide monitoring data. Sulotto et al. (1990) and Musk et al. (1982) did not find declines in lung function in workers. Sulotto et al. (1990) reported MDI levels ranging from 0.005 to 0.001 ppm; the monitoring data provided by Musk et al. (1982) was not considered reliable.

[underlined: Agency Contacts (Chemical Managers)]: Malcolm Williams