# 8 REFERENCES

* Cited in text

*AIHA. 1992. Emergency response planning guidelines. American Industrial Hygiene Association.
*AIHA. 1994. Workplace environmental exposure level. American Industrial Hygiene Association.
*Anonymous. 1975. Analytical guide for Ti metal and Ti dioxide. Am Ind Hyg Assoc J 36:707–708.1180225
*Anonymous. 1990. Liquefied gaseous fuels spill test facility program: Eleven additional chemicals: Environmental assessment. Govt Reports Announcements & Index (GRA&I) 15. NTIS/DE90008109.
*Anson BJ, Harper DG, Winch TR. 1956. Intra-osseous blood supply of the auditory ossicles in man. Ann Otolaryngol 73:645–650.13363098
*Ashby J, Mohammed R. 1986. Slide preparation and sampling as a major source of variability in the mouse micronucleus assay. Mutat Res 164:217–235.3748060
*ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles. Agency for Toxic Substances and Disease Registry, Division of Toxicology, Atlanta, GA.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
*Browning E. 1969. Toxicity of industrial metals. 2nd ed. New York, NY: Appleton-Century-Crofts, 331–335.
*CAA. 1990. Clean Air Act. United States Code 42 USC 7412.
*CAAA. 1990. Clean Air Act Amendments. Washington, DC: Public Law 101–549, Title III, Section 112 B.
*Cast0 BC, Meyers J, DiPaulo JA. 1979. Enhancement of viral transformation for evaluation of the carcinogenic or mutagenic potential of inorganic metal salts. Cancer Res 39:193–198.570089
*CELDS. 1993. Computer-aided Environmental Legislative Data Systems. University of Illinois, Urbana, IL. March 9, 1993.
*Chakrabarti CL, Katyal M. 1971. Indirect determination of titanium by atomic absorption spectrophotometry.. Anal Chem 43( 10): 1302–1303. -.
*Chen JL, Fayerweather WE. 1988. Epidemiologic study of workers exposed to titanium dioxide. J Occup Med 30(12):937–942.3230444
*Chitkara DK, McNeela BJ. 1992. Titanium tetrachloride bums to the eye. Br J Ophthalmol 76(6):380–382.1622953
*CHRIS. 1985. Chemical Hazard Response Information System. Hazard assessment handbook. Washington, DC: U.S. Department of Transportation, U.S. Coast Guard. Commandant Instruction M.16465.12A.
*CICIS. 1993. Chemicals In Commerce Information System. Titanium chloride. United States Environmental Protection Agency, Information Management Division, Confidential Data Branch, Washington, DC. April 5, 1993.
*Cox PH. 1976. Technetium bone-scanning complexes (letter). Br J Radio1 49(597):297–298.
*Cracker IH, Merritt WF. 1972. Analysis of environmental samples by spark source mass spectrometry trace elements in water. Water Res 6:285–295.
*Dams R, Rahn KA, Winchester JW. 1972. Evaluation of filter materials and impaction surfaces for nondestructive neutron activation analysis of aerosols. Environ Sci Technol 6(5):441–448.
*Dams R, Robbins JA, Rahn KA, 1970. Nondestructive neutron activation analysis of air pollution particulates. Anal Chem 42(8):861–867.5431523
*DiPaulo JA, Casto BC. 1979. Quantitative studies of in vitro morphological transformation of Syrian hamster cells by inorganic metal salts. Cancer Res 39:1008–1013.427740
*Dittrich TR, Cothern CR. 1971. Analysis of trace metal particulates in atmospheric samples using x-ray fluorescence. J Air Pollut Control Assoc 21(11):716–719.
*DOE. 1978. A risk analysis of exposure to high concentrations of cold smoke. Washington, DC: U.S. Department of Energy, Division of Operational Safety. ISS SAND-78–0544.
*DOT. 1987. Optional hazardous materials table. Department of Transportation. Code of Federal Regulations. 49 CFR 172.102.
*DOT. 1989. Hazardous materials table. Department of Transportation. Code of Federal Regulations. 49 CFR 172.101.
*DOT. 1991. Regulations for elevated temperature materials. Department of Transportation. Code of Federal Regulations. 49 CFR 173.247.
*DuPont Company. 1979. Four-week Inhalation study with titanium tetrachloride. Haskell Laboratory Report No. 459–479.
*DuPont Company.. 1980. Acute inhalation studies with titanium tetrachloride. Haskell.Laboratory Report No. 658–680.
*DuPont Company. 1994. Written communication (December 9) to David Satcher, Administrator, ATSDR, regarding comments on Toxicological Profile for Titanium Tetrachloride (Draft for Public Comment).
*Durum WH, Haffty J. 1961. Occurrence of minor elements in water. US Geological Survey Circular 445: 1–11.
*Elo R, Maatta K, Uksila E, 1972. Pulmonary deposits of titanium dioxide in man. Arch Path01 94:417–424.
*EPA. 1971. Tolerances and exemptions from tolerances for pesticide chemicals in or on raw agricultural commodities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.1001(d).
*EPA. 1984. U.S. Environmental Protection Agency. Preliminary results of a two-year inhalation study on rats with titanium tetracloride. EPA no. SEHQ-0984–0.530.
*EPA. 1985a. BPT and BAT limitations for primary and secondary titanium subcategory. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 421.300–421.306.
*EPA. 1985b. Titanium tetrachloride (CASRN: 7550–45-o): EPA chemical profiles. Washington, DC: U.S. Environmental Protection Agency.
*EPA. 1986. Two-year inhalation study with titanium tetrachloride in rats, final report (Vols. I & II). Washington, D.C. U.S. Environmental Protection Agency. EPA No. 8EHQ-0386–0530. Microfiche No. OTS0509697.
*EPA. 1987. Epidemiological study of lung cancer, chronic respiratory disease, and pulmonary x-ray abnormalities in workers exposed to Ti02 and TiC14. Washington, DC: U.S. Environmental Protection Agency. EPA No. 8EHQ--0887–0530. Microfiche No. OTS0509697–1.
*EPA. 1988a. Environmental Protection Agency. Reportable quantity adjustments. 40 CFR 372.65.
*EPA. 1990a. Interim Methods for Development of Inhalation Reference Doses. Washington, DC. U.S. Environmental Protection Agency. EPA/600/8–90/066A.
*EPA. 1990b. Epidemiologic study of lung cancer mortality in workers exposed to titanium tetrachloride and cigarette smoke: A reanalysis (final report). Washington, DC: U.S. Environmental Protection Agency. EPA No. 8EHQ-0990–0530.
*EPA. 1990~. List of extremely hazardous substances and their threshold planning quantities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR Appendix A Part 355.
*EPA. 1991. Toxic chemical release reporting: Community right-to-know. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.
*EPA. 1993. Environmental Protection Agency. Specific toxic chemical listings. 58 FR 54836. 40 CFR
*Fayerweather WE; Karns ME, Gilby PG, .1992. Epidemiologic study of lung cancer mortality in workers exposed to titanium tetrachloride. J Occup Med 34(2):164–169.1597772
*FDA. 1977a. Contact lens coloring regulations. Food and Drug Administration. Code of Federal Regulations. 21 CFR 73.2575.
*FDA. 1977b. Drug coloring regulations. Food and Drug Administration. Code of Federal Regulations. 21 CFR 73.1575.
*FDA. 1977~. Regulations for components of the food-contact surface of paper and paperboard food packaging. Food and Drug Administration. Code of Federal Regulations. 21 CFR 176.170(b)(2).
*FDA. 1982. Cellophane usage and constituent limitations. Food and Drug Administration. Code of Federal Regulations. 21 CFR 177.1200.
*FDA. 1983. Indirect food additives: Adhesives and components of coatings. Food and Drug Administration. Code of Federal Regulations. 21 CFR 175.105.
*FDA. 1984. Listing of color additives exempt from certification. Food and Drug Administration. Code of Federal Regulations. 21 CFR 73.575.
*FDA. 1986. Cosmetic coloring regulations. Food and Drug Administration. Code of Federal Regulations. 21 CFR 73.3126.
*FDA. 1987. Food, drug, contact lens and cosmetic coloring regulations. Food and Drug Administration. Code of Federal Regulations. 21 CFR 70.25.
*FDA. 1989a. Federal Food, Drug and Cosmetic Act. Washington, DC: Food and Drug Administration. Sections 510(k),515,520(g).
*FDA. 1989b. Prior-sanctioned food ingredients. Food and Drug Administration. Code of Federal Regulations. 21 CFR 181.30.
*FEDRIP. 1995. Federal Research in Progress. Production of Titanium powder by vapor phase reduction. Bureau of Mines. Albany Research Center.
*Ferin J, Coleman JR, Davis S, 1976. Electron microprobe analysis of particle deposited in lungs. Arch Environ Health 3 1: 113–115.
*Friberg L, Nordberg GR, Vouk VB. 1986. Handbook on the toxicology of metals. New York, NY: Elsevier North Holland, 630.
*Garabrant DH, Fine LJ, Oliver C, 1987. Abnormalities of pulmonary function and pleural disease among titanium metal production workers. Stand J Work Environ Health 13(1):47–51.
*Giauque RD, Goda LY, Brown NE. 1974. Characterization of aerosols in California by x-ray-induced x-ray fluorescence analysis. Environ Sci Technol 8:436–441.
*Glassroth J. 1984. Diffuse endobronchial polyposis following a titanium tetrachloride inhalation injury [letter]. Am.Rev Respir Dis 130(6):1189.6508015
*Grant WM, ed. 1986. Toxicology of the eye. Springfield, IL: Charles C. Thomas Publisher, 919.
*Haddad LM, Winchester JF. 1990. Clinical management of poisoning and drug overdose. 2nd ed. Philadelphia, PA: W.B. Saunders Company, 1028–1034.
*HAZDAT. 1995. Database. Agency for Toxic Substances and Disease Registry (ATSDR). Alanta GA.
*HSDB. 1992. Hazardous Substances Data Bank. Titanium tetrachloride and titanium dioxide. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. December 16. 1992.
*HSDB. 1995. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Program (via TOXNET), Bethesda, MD. January 1995.
*Hsie AW, Johnson NP, Couch DB,‘ 1979. Quantitative mammalian cell mutagenesis and a preliminary study of the mutagenic potential of metallic compounds. In: Kharasch N, ed. Trace metals in health and disease. New York, NY: Raven Press, 55–69.
*Hwang JY. 1972. Trace metals in atmospheric particulates. Anal Chem 44(14):20A-27A
*IRPTC. 1985. Treatment and disposal methods for waste chemicals. International register of potentially toxic chemicals. United Nations Environment Programme. Geneva, Switzerland.
*ITII. 1984. Toxic and Hazardous industrial chemicals safety manual for handling disposal with toxicity and hazard data. The International Technical Information Institute.
*Johansson TB, van Grieken RE, Nelson JW, 1975. Elemental trace analysis of small samples by proton induced x-ray emission. Anal Chem 47(6):855–860.
*Kada T, Hirano K, Shirasu Y. 1980. Screening of environmental chemical mutagens by the ret-assay system with bacillus subtilis. Chemical Mutagens 6:149–173.
*Kamrin MA. 1992. Workshop on the health effects of HCl in ambient air. Regul Toxicol Pharmacol 15(1):73–82.1553414
*Kanematsu N, Hara M, Kada T. 1980. Ret assay and mutagenicity studies on metal compounds. Mutat Res 77:109–l 16.6769036
*Karlsson N, Cassel G, Fangmark I, 1986. A comparative study of the acute inhalation toxicity of smoke from Ti02-hexachloroethane and Zn-hexachloroethane pyrotechnic mixtures. Arch Toxicol 59(3):160–166.3813883
*Kastenbaum MA, Bowman KO. 1970. Tables for determining the statistical significance of mutation frequencies. Mutat Res 9:527–549.5424720
*Kelly DP, Lee KP, Burgess BA. 1981. Inhalation toxicity of titanium tetrachloride atmospheric hydrolysis products [Abstract]. Toxicologist 1:76–77.
*Kirkbright GF; Smith AM, West TS, .1969. An indirect amplification procedure for the determination of titanium by atomic-absorption spectroscopy. Analyst 94:754–759.
*Klaassen CD, Amdur MD, Doull J, eds. 1980. Casarett and Doull’s toxicology. 3rd ed. New York, NY: Macmillan Publishing Co., 627–628.
*Landsberger S, Davies TD, Tranter M, 1989. The solute and particulate chemistry of background versus a polluted, black snowfall on the Caimgorm Mountains, Scotland. Atmos Environ 23(2):395–401.
*Lawson JJ. 1961. The toxicity of titanium tetrachloride. J Occup Med 3(1):7–12.13759720
*Lee KP, Kelly DP, Schneider PW, 1986. Inhalation toxicity study on rats exposed to titanium tetrachloride atmospheric hydrolysis products for two years. Toxicol Appl Pharmacol 83(1):30–45.3952749
*Lee KP, Trochimowicz HJ, Reinhardt CF. 1985. Pulmonary response of rats exposed to titanium dioxide (Ti02) by inhalation for two years. Toxicol Appl Pharmacol 79:179–192.4002222
*Leone JL. 1973. Collaborative study of the quantitative determination of titanium dioxide in cheese. J Assoc Off Anal Chem 56(3):535–537.4779889
*Luckey TD, Venugopal B. 1977. Metal toxicity in mammals. Vol. 1. New York, NY: Plenum Press, 176–178.
*Merck Index. 1989. Merck index: an encyclopedia of chemicals, drugs, and biologicals. 11th ed. Budavari S, ed. Rahway NJ: Merck & Co., Inc.
*Mezentseva NV, Melnikova EA, Mogilevskaya OY A. 1963. In: Izrael’son ZI, ed. Toxicology of the rare metals, 35–43. (translated from Russian by the Israel program for scientific translations, Jerusalem, 1967). Gosudarstvennoe Izdatel’stvo Medicinskoi Literatury, Moscow.
*Mogilevskaja OJa. 1983. Titanium, alloys and compounds. In: Parmeggiani L, ed. Encyclopedia of Occupational Health and Safety 2:2179–2181.
*Moseley C, Garabrant D, Fine L. 1982. Health hazard evaluation report no. HE-79–17-751 at RMI metals reduction plant, Ashtabula, OH. National Institute for Occupational Safety and Health, Division of Surveillance. NTIS PB 82–103243.
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
*NATICH. 1992. Titanium chloride. National Air Toxics Information Clearinghouse. Data base report on state, local, and EPA air toxics activities. US Environmental Protection Agency, Office of Air Quality Planning and Standards, Washington, DC. September,1992.
*NFPA. 1994. Fire protection guide to hazardous materials. National Fire Protection Association. One Batterymarch Park, Quincy, MA. 49–l27.
*NIOSH. 1980. Health hazard evaluation report No. HE-79–17-751 at RMI metals reduction plant, Ashtabula, OH. Cincinnati, OH: National Institute for Occupational Safety and Health, Hazard Evaluations and Technical Assistance Branch, Division of Surveillance, Hazard Evaluations and Field Studies. NTIS/PB82–103243.
*NIOSH. 1984. Manual of analytical methods. 3rd ed. Eller PM, ed. Cincinnati, OH: National Institute for Occupational Safety and Health. Publication no. 84–100, Methods 7300 and 8310.
*NIOSH. 1992. Recommendations for occupational safety and health: Compendium of policy documents and statements. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health.
*NIOSH. 1993. National occupational exposure survey. Cincinnati, OH: National Institute for Occupational Safety and Health.
*NIOSH. 1994a. Method 8310. Metals in urine. In: NIOSH Manual of Analytical Methods 4th ed. National Institute for Occupational Safety and Health. Centers for Disease Control and Prevention. Public Health Service. U. S. Department of Health and Human Services.
*NIOSH. 1994b. Method 0500. Particulates not otherwise regulated, total. In: NIOSH manual of analytical methods 4th ed. National Institute for Occupational Safety and Health. Centers for disease Control and Prevention. Public Health Service . U. S. Department of Health and Human Services.
*NIOSH. 1994c. Method 0600. Particulates not otherwise regulated, respirable. In: NIOSH manual of analytical methods 4th ed. National Institute for Ocupational Safety and Health. Centers for Disease Control and Prevention. Public Health Service. U. S. Department of Health and Human Services.
*NIOSH. 1994d. Method 7300. Elements by ICP. In: NIOSH manual of analytical methods 4th edition. National Institute for Occupational Safety and Health. Centers for Disease Control and Prevention. Public Health Service. U. S. Department of Health and Human Services.
*Nordman H, Berlin M. 1986. Titanium. In: Friberg L, Nordberg GF, Vouk V, , eds. Handbook of the toxicology of metals. 2nd ed. Amsterdam: Elsevier Science Publishers B.V., 595–609.
*NREPC. 1986. Acceptable ambient limits and significant emission levels of toxic air pollutants. Frankfurt, KY: Natural Resources and Environmental Protection Cabinet, Department for Environmental Protection, Division of Air Pollution.
*Ogawa HI, Tsuruta S, Niyitani Y, 1987. Mutagenicity of metal salts in combination with 9aminoacridine in Salmonella typhimurium. Jpn J Genet 62(2):159–162.
*OHM/TADS. 1992. Titanium tetrachloride. Oil and Hazardous Materials/Technical Assistance Data System. Chemical Information Systems, Inc. December, 1992.
*Ophus EM, Rode L, Gylseth B, 1979. Analysis of titanium pigments in human lung tissue. Stand J Work Environ Health 5:290–296.
*OSHA. 1992, Limits for air contaminants. Occupational Safety and Health Administ_ration. Code of Federal Regulations. 29 CFR 19 10.1000.
*OTA. 1990. Neurotoxicology: Identifying and controlling poisons of the nervous system. Office of Technology Assessment, Washington, DC. OTA-BA-438.
*Ottaway JM, Coker DT, Davies JA. 1970. A sensitive indirect method for the determination of titanium by atomic absorption spectrophotometry using an air-acetylene flame. Anal Lett 3(7):385–392.
*Park T, DiBenedetto R, Morgan K, 1984. Diffuse endobronchial polyposis following a titanium tetrachloride inhalation injury. Am Rev Respir Dis 130(2):315–317.6380360
*Pelizetti E, Miner0 C, Maurino V. 1990. The role of colloidal particles in the photodegradation of organic compounds of environmental concern in aquatic systems. Advances in Colloid and Interface Science 32(2–3):271–316.
*Pigg CJ A, Stocum WE, Gray CE, 1978. A risk analysis of exposure to high concentrations of cold smoke. Report: ISS SAND-78–0544.
*Pritchard JN. 1989. Dust overloading - a case for lowering the TLV of nuisance dusts? J Aerosol Science 20(8):1341–1344.
*Ranweiler LE, Moyers JL. 1974. Atomic absorption procedure for analysis of metals in atmospheric particulate matter. Environ Sci Technol 8:152–156.
*Redline S, Bama BP, Tomashefski JF, 1986. Granulomatous disease associated with pulmonary deposition of titanium. Br J Ind Med 43(10):652–656.3778834
*Rhodes JR, Pradzynski AH, Hunter CB, 1972. Energy dispersive x-ray fluorescence analysis of air particulates in Texas. Environ Sci Technol 6:922–927.
*ROSS DS. 1985. Exposure to titanium tetrachloride. Occup Health 37(11):525.
*RTECS. 1992. Titanium tetrachloride. Registry of Toxic Effects of Chemical Substances. Cincinnati, OH: National Institute of Occupational Safety and Health. August 20, 1992.
*Sax NI, Lewis RJ Sr. 1989. Dangerous properties of industrial materials. Seventh edition. New York, NY: Van Nostrand Reinhold.
*Slavin W, Manning DC. 1963. Atomic absorption spectrophotometry in strongly reducing oxyacetylene flames. Anal Chem 35(2):253–254.
*Smith DM, Pigg CJ, Archuleta RF. 1980. Biological effects of inhaled TiC14/NH40H reaction products in Sprague-Dawley rats and Syrian hamsters. Report ISS LA-8654-MS.
*Snee RD, Irr JD. 1981. Design of a statistical method for the analysis of mutagenesis at the hypoxanthine-guanine phosphoribosyl transferase locus of cultured Chinese hamster ovary cells. Mutat Res 85:77–93.7196495
*Stokinger HE. 1981. Titanium. In: Clayton GD, Clayton FE, eds. Patty’s industrial hygiene and toxicology. Volume 2A: Toxicology. 3rd ed. New York, NY: John Wiley & Sons, _. 1968–1981.
*TRI91. 1993. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*TRI92. 1994. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*TRI93. 1995. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda MD.
*Tsujii H, Hoshishima K. 1979. The effect of the administration of trace amounts of metals to pregnant mice upon the behavior and learning of their offspring. Shinshu Daigaku Nogakubu Kiyo (Journal of the Faculty of Agriculture Shinshu University) 16:13–28.
*Whitehead J. 1983. Titanium compounds. In: Grayson M, Eckroth D, eds. Encyclopedia of chemical technology, 3rd ed. Vol. 23: Thyroid and antithyroid preparations to vinyl polymers. New York, NY: John Wiley & Sons, 159–163.
*Wilms EB, van Xanten NH W, Meulenbelt J. 1992. Smoke producing and inflammable materials. Govt Reports Announcements & Index (GRA&I), Issue 01. NTIS/PB92–104967.
*Yound JP, White JC. 1959. Extraction of titanium thiocyanate with tri-n-octylphosphine oxide. Anal Chem 31(3):393–397.