# 4 PRODUCTION, IMPORT/EXPORT, USE, AND DISPOSAL

## 4.1 PRODUCTION

Titanium tetrachloride is a colorless-to-light-yellow watery liquid that is produced by the chlorination of titanium compounds by a continuous process in a fluid-bed reactor. Minerals with a high titanium content, such as beneficiated ilmenite, mineral r-utile, and leucoxene, are used in the production of titanium tetrachloride. Carbon (usually as coke) is also added during the chlorination process as a reducing agent because the titanium compounds contain oxygen (Whitehead 1983).

The estimated production of titanium tetrachloride in the United States in 1972 was at least 5,670,000,000 grams (12,474,000 pounds) (HSDB 1995); in 1975, it was at least 9,500,000,000 grams (20,900,000 pounds) (HSDB 1995); and in 1980, it was 2,500,000 tons (5,000,000,000 pounds) (Whitehead 1983). More recently, the aggregate production volume for titanium tetrachloride reported in the Toxic Substances Control Act Inventory for 1990 was 3,150,556,000 pounds (1,575,278 tons) (CICIS 1993).

A list of titanium tetrachloride production and processing facilities in the United States along with the production or processing volume for each facility are provided in Table 4-1 (TR193 1995). Table 4-1 lists the facilities in each state that manufacture or process titanium tetrachloride, the intended use, and the range of maximum amounts of titanium tetrachloride that are stored on site. The data listed in Table 4-1 are derived from the Toxics Release Inventory (TR193 1995). The TRI data should be used with caution since only certain types of facilities are required to report. Therefore, this is not an exhaustive list.

## 4.2 IMPORT/EXPORT

No information on import or export volumes for titanium tetrachloride was located.

## 4.3 USE

Titanium tetrachloride is used as an intermediate in the manufacture of titanium metal, titanium dioxide, titanous chloride pigments, iridescent glass, artificial pearls, and as a starting material for a variety of organic and inorganic titanium compounds. It is also used as a mordant dye, a polymerization catalyst, and as a catalyst in many organic syntheses in the chemical industry (Chitkara and McNeela 1992; EPA 1985b; Merck 1989; Nordman and Berlin 1986; OHM/TADS 1992; Stokinger 1981; Whitehead 1983).

Table 4-1 Facilities That Manufacture or Process Titanium Tetrachloride

Facility | Location^a^ | Range of maximum amounts on-site in pounds | Activities and uses
DU PONT | AXIS, AL | 100,000–999,999 | As a reactant
DU PONT | ANTIOCH, CA | 100,000–999,999 | Produce; For on-site use/processing; As a reactant
PFIZER INC. | CT | 10,000–99,999 | As a reactant; As a Chemical Processing aid
DU PONT | EDGEMOOR, DE | 1,000,000–9,999,999 | Produce; For on-site use/processing; For sale/distribution; As a reactant
KEMIRA INC. | SAVANNAH, GA | 1,000,000–9,999,999 | Produce; For on-site use/processing; For sale/distribution; As a reactant
AMERICAN SYNTHETIC RUBBER | LOUISVILLE, KY | 10,000–99,999 | As a Chemical Processing aid
LOUISIANA PIGMENT CO. L.P. | WESTLAKE, LA | 100,000–999,999 | Produce; For on-site use/processing; As a reactant
HIMONT USA INC. | LAKE CHARLES, LA | 100,000–999,999 | As a reactant
SHELL NORCO MFG. COMPLEX | NORCO, LA | 100,000–999,999 | As a reactant
SCM CHEMICALS | BALTIMORE, MD | 1,000,000–9,999,999 | Produce; For on-site use/processing; As a reactant
AKZO CHEMICALS INC. | WESTON, MI | 10,000–99,999 | In repackaging
ANDERSON DEVELOPMENT CO. | ADRIAN, MI | 10,000–99,999 | As a reactant
DU PONT DELISLE | PASS CHRISTIAN, MS | 1,000,000–9,999,999 | Produce; For on-site use/processing; As a reactant
KERR-MCGEE CHEMICAL CORP. | HAMILTON, MS | 1,000,000–9,999,999 | Produce; For on-site use/processing; As a reactant
HUNTSMAN POLYPROPYLENE CORP. | WEST DEPTFORD TWP., NJ | 10,000–99,999 | As a Chemical Processing aid
AKZO NOBEL CHEMICALS INC. | EDISON, NJ | 100,000–999,999 | As a reactant
E. I. DU PONT DE NEMOURS & CO. | NJ | 100,000–999,999 | As a reactant
TITANIUM METALS CORP. | HENDERSON, NV | 1,000,000–9,999,999 | Produce; For on-site use/processing; For sale/distribution; As a reactant
TAM CERAMICS INC. | NIAGARA FALLS, NY | 10,000–99,999 | As a reactant
CORNING INC. | NY | 10,000–99,999 | As a reactant
SCM CHEMICALS | ASHTABULA, OH | 1,000,000–9,999,999 | Produce; For on-site use/processing; As a reactant
SCM CHEMICALS AMERICAS | ASHTABULA, OH | 1,000,000–9,999,999 | Produce; For on-site use/processing; As a reactant
PHILLIPS RESEARCH CENTER | BARTLESVILLE, OK | 10,000–99,999 | As a reactant; Ancillary uses
OREGON METALLURGICAL CORP. | ALBANY, OR | 1,000,000–9,999,999 | As a reactant
PFIZER INC. | PR | 10,000–99,999 | As a reactant
DU PONT | NEW JOHNSONVILLE, TN | 1,000,000–9,999,999 | Produce; For on-site use/processing; As a reactant
AMOCO CORP. | TX | 10,000–99,999 | As a Chemical Processing aid
SOLVAY AMERICA INC. | TX | 10,000–99,999 | As a Chemical Processing aid
CATALYST RESOURCES | PASADENA, TX | 10,000–99,999 | As a reactant
ETHYL CORP. | PASADENA, TX | 10,000–99,999 | As a Chemical Processing aid
CHEVRON CORP. | TX | 10,000–99,999 | As a Chemical Processing aid
NA | TX | 10,000–99,999 | As a reactant
TEXAS EASTMAN DIV. | LONGVIEW, TX | 10,000–99,999 | As a reactant; Ancillary uses
GOODYEAR TIRE & RUBBER CO. | CHEEK, TX | 10,000–99,999 | As a Chemical Processing aid
OCCIDENTAL CHEMICAL CORP. | WADSWORTH, TX | 10,000–99,999 | As a Chemical Processing aid
OCCIDENTAL PETROLEUM CORP. | TX | 10,000–99,999 | As a Chemical Processing aid
E. I. DU PONT DE NEMOURS & CO. | TX | 10,000–99,999 | As a Chemical Processing aid
AKZO NOBEL CHEMICALS INC. | GALLIPOLIS FERRY, WV | 10,000–99,999 | As a Chemical Processing aid

Source: TRI93 1995

a Post office State abbreviation used

Titanium tetrachloride was formerly used with potassium bitartrate as a mordant in the textile industry, with dyewoods to dye leather, and as a smoke-producing screen with ammonia for the military (Merck 1989; Whitehead 1983).

## 4.4 DISPOSAL

The recommended disposal methods for titanium tetrachloride (including its container) include disposal in a landfill or by incineration (IRPTC 1985; OHM/TADS 1992). Small spills or leaks of titanium tetrachloride should be covered with a sufficient amount of sodium bicarbonate. The mixture should be removed and placed in an appropriate container such as a fiber drum, plastic bag, or carton, and then incinerated (IT11 1984; OHM/TADS 1992). Alternatively, titanium tetrachloride spills may be spread in a thin layer on the ground and dispersed by large amounts of water into a sewer. Spill areas should be washed thoroughly. The local waste water treatment authority should be notified of any discharge (IT11 1984).

No additional information on disposal methods for titanium tetrachloride was located.