# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Information regarding the chemical identity of titanium tetrachloride is located in Table 3-1.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of titanium tetrachloride is located in Table 3-2.

Table 3-1 Chemical Identity of Titanium Tetrachloride

Characteristic | Information | Reference
Chemical name | Titanium tetrachloride | HSDB 1995
Synonym(s) | Tetrachlorotitanium, titanic chloride, titanium chloride, others | HSDB 1995
Registered trade name(s) | No data
Chemical formula | TiCl_4_ | HSDB 1995
Chemical structure | [image] | OHM/TADS 1992
Identification numbers:
CAS registry | 7550-45-0 | HSDB 1995
NIOSH RTECS | XR1925000 | HSDB 1995
EPA hazardous waste | No data | HSDB 1995
OHM/TADS | 7217310 | HSDB 1995
DOT/UN/NA/IMCO shipping | IMCO/UN: #8.0/1838; DOT: #1838 | CHRIS 1985
HSDB | 870 | HSDB 1995
NCI | No data

CAS = Chemical Abstracts Service; CHRIS = Chemical Hazards Response Information System; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substance Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materiais/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 3-2 Physical and Chemical Properties of Titanium Tetrachloride

Property | Information | Reference
Molecular weight | 189.70 | Sax and Lewis 1989
Color | Colorless | Merck 1989
Physical State | Liquid | CHRIS 1985
Melting point | −24.1 °C | Merck 1989
| −24 °C | NFPA 1994
Boiling point | 136.4 °C | Merck 1989
Density:
at 20 °C | 1.726 g/cm^3^ | Merck 1989
Odor | Penetrating acid odor | Merck 1989
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 20 °C | Soluble in cold water | Merck 1989
| Reacts | NFPA 1994
Organic solvent(s) | Soluble in alcohol | Merck 1989
Partition coefficients:
Log K_ow_ | No data
Log K_oc_ | No data
Vapor pressure
at 20 °C | 10.0 mm Hg | Whitehead 1983
at 22 °C | 9.6 mm Hg | NFPA 1994
Henry’s law constant:
at 20 °C | No data
at 30 °C | No data
Autoignition temperature | No data
Flashpoint | No data
Flammabiiity limits | Nonflammable | OHM/TADS 1992
Conversion factors | 1 mg/m^3^ = 7.76 ppm^a^ | Calculated
| 1 ppm = 0.129 mg/m^3^ | Calculated
Explosive limits | Reactive only under extreme conditions | OHM/TADS 1992

a 1 mg/m^3^ = 1 ppm × 189.70/24.45

CHRIS = Chemical Hazards Response Information System; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; NFPA = National Fire Protection Association