# APPENDIX A MINIMAL RISK LEVEL (MRL) WORKSHEETS

## Titanium tetrachloride Intermediate Inhalation

Chemical Name: | Titanium tetrachloride
CAS Number: | 7550-45-O
Date: | November 14, 1995
Profile Status: | Tdird Draft Post Public Comment
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 5r
Species: | Rat

[underlined: Minimal Risk Level]: 0.01 [X] mg/m^3^ [ ] ppm

[underlined: Reference]: DuPont 1979

[underlined: Experimental design]: (human study details or strain, number of animals per exposure/control groups, sex, dose administration details): Male Charles River (CD) rats (25/exposure concentration) were exposed to 0, 5, 10, or 40 mg/m^3^ of atmospheric titanium tetrachloride allowed to hydrolyze in normal air for 6 hours/day, 5 days/week, for 4 weeks. Hematology, clinical chemistry, and urine tests, were conducted on 10 rats/group after the last exposure and after a 2-week recovery period. Five rats/group were necropsied on the last exposure day, after 2 weeks, and at 3, 6, and 12 months post-exposure. Blood and urine δ-aminolevulinic acid were determined at l-week intervals during the exposure period and 2 weeks post-exposure. All major organs and tissues were examined grossly and microscopically.

[underlined: Effects noted in study and corresponding doses]: Two rats in the high-exposure group died on test days 15 and 23. Death was attributed to respiratory failure triggered by partial obstruction of the tracheal lumen with precipitated dust particles, denuded tracheal epithelium, acute obliterative bronchiolitis, interstitial pneumonitis, pulmonary edema, and hemorrhage. In the high-exposure group, body weight gain was depressed by about 19% relative to controls by the end of the 4-week exposure period, but this trend was reversed during the recovery period. Treatment-related effects consisted of a decrease in δaminolevulinic acid dehydrase, a decrease in BUN and urine osmolality, and higher urinary pH in the mid- and high-exposure groups; these values returned to normal after a 2-week recovery period. Results from clinical chemistry and hematology tests revealed no significant deviations from normal ranges. Results from pathological examination showed that rats in the low-exposure group, sacrificed up to one year after exposure, had only a mild lung dust cell reaction. The mid- and high-exposure groups showed a concentration-dependent inflammation of the respiratory tract. Alterations consisted of acute bronchiolitis, interstitial pneumonitis, proliferation of alveolar cells, and hyperplasia of the tracheal epithelium with hypermucous secretion. These lesioins gradually disappeared after recovery and dust cells became sharply focalized. Collagenized fibrosis in the bronchioles and adjoining alveolar walls persisted throughout the 12-months recovery period. Relative lung weight was significantly elevated in all treated groups on the last exposure day and on the mid-and high-exposure groups 2 weeks post-exposure. Lung weight returned to normal 3 months post-exposure. There were no compound-related pathological lesions in the other organs and tissues examined.

[underlined: Dose and end point used for MRL derivation]: The 5 mg/m^3^ exposure concentration is considered a less serious LOAEL for mild dust cell reaction and increased relative lung weight.

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 3 for use of a minimal LOAEL
- [X] 3 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] No

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Rats were exposed in stainless steel chambers under dynamic air conditions. No information was provided regarding the method for generating the titanium tetrachloride atmospheric hydrolysis products. Because the rats were exposed to an aerosol and the critical effect was respiratory, Equation 4-5 in Interim Methods for Development of Inhalation Reference Concentrations (EPA 1990) was used to calculate the HEC (Human Equivalent Concentration). However, the only information provided regarding the size parameters of the aerosol particles was that the diameter ranged from 1 to 400 pm. Therefore, a default method was used to determine the ratio of the dose available for uptake from the thoracic region of the experimental animal species to that of humans (RDDR_TH_). Examination of Table H-1 in EPA (1990) revealed that the most conservative value of RDDRTH for any sigma g for the thoracic region is 0.2064. The LOAEL_HEC_ was thus calculated as follows:

- LOAEL_HEC_
- = LOAEL × RDDR_TH_ = 5 mg/m^3^ × 0.2064
- = 1.032 mg/m^3^

where:

LOAEL_HEC_ = Human Equivalent Concentration of the LOAEL (lowest-observed-adverse effect level)

RDDR_TH_ = Regional Deposited Dose Ratio for Respiratory Effects in the Thoracic Region

Thus, the proposed intermediate inhalation MRL is derived as follows:

- MRL = LOAEL_HEC_ ÷ UF
- MRL = 1.032 mg/m^3^ ÷ 90
- MRL = 0.01 mg/m^3^

[underlined: Was a conversion used from intermittent to continuous exposure?] No

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Several studies in humans lend support to deriving a MRL. A health hazard evaluation of workers employed in a metal reduction factory suggests that exposure to titanium tetrachloride and its hydrolysis products may cause pulmonary impairment (Garabrant et al. 1987; Moseley et al. 1982). The data from those studies support the notion that chronic exposure to titanium tetrachloride may result in restrictive pulmonary changes. However, the concomitant exposure to other chemicals, such as titanium oxide, titanium dichloride, titanium oxychloride, sodium, sodium hydroxide, and sodium oxide prevents a more definitive determination of the role of titanium tetrachloride. Irritation of the upper and lower respiratory tract is observed in humans following acute inhalation exposure to titanium tetrachloride (Park et al. 1984; Ross 1985). The respiratory irritation may lead to cough, wheezing, dyspnea, respiratory distress, and hypoxia. In some cases, impairment of the respiratory function may continue for several weeks following exposure (Park et al. 1984).

Acute inhalation studies in animals lend support for a MRL derivation. Acute exposure of rats to 1,466, 5,122, 7,529 and 11,492 mg/m^3^ of titanium tetrachloride resulted in wet noses, nasal discharge, dyspnea, and swollen eyelids (Karlsson et al. 1986). No deaths were found. Histopathology performed 7 days after exposure was essentially normal and revealed only minor lung lesions. The lungs in l/3 and 2/2 animals exposed to 5,122 and 11,492 mg/m^3^, respectively, showed discrete inflammatory residues, coarsened alveolar septa, and sparse accumulation of phagocytes. Rats exposed to 1,200 mg/m^3^ titanium tetrachloride for 30 minutes had severe inflammation of the respiratory epithelium 1 day post-exposure (DuPont 1980). Forty-nine days post-exposure the respiratory epithelium had normal appearance.

In a chronic study, Sprague-Dawley rats (l00/sex/exposure concentration) were exposed to 0, 0.1, 1.0, or 10.0 mg/m^3^ of atmospheric titanium tetrachloride allowed to hydrolyze in normal air for 6 hours/day, 5 days/week, for 104 weeks. The most significant finding was the increased incidence of rhinitis and tracheitis with exposure concentration. In the low-exposure group the incidence of rhinitis was also duration-dependent and ranged from 4.3 to 15% after 1 year of treatment, and from 22 to 64% at the end of the second year. Similar observations were made in the mid- and high-exposure groups. Tracheitis also increased with exposure duration, and to a lesser degree with concentration. The two highest groups had increased incidence of tracheitis as early as 3 months, and at the end of 2 years was also increased in the lowest exposure group. The incidences of tracheitis at the end of the 2 years were O-2.5%, 12-20%, 41-49%, and 30-44% for the control, low-, mid-, and high-exposure groups, respectively. Gross pathology and histopathology revealed compound-related changes in the lungs and thoracic lymph nodes of the treated animals.

Agency Contact (Chemical Manager): Ed Murray

## Titanium tetrachloride Chronic Inhalation

MINIMAL RISK LEVEL WORKSHEET

Chemical Name: | Titanium tetrachloride
CAS Number: | 7550-45-0
Date: | November 14, 1995
Profile Status: | Third Draft Post Public Comment
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 6r
Species: | Rat

[underlined: Minimal Risk Level]: [underlined: 0.0001] [X] mg/m^3^ [ ] ppm

[underlined: Reference:] EPA 1986; Lee et al. 1986

[underlined: Experimental design]: (human study details or strain, number of animals per exposure/control groups, sex, dose administration details): Charles River (CD) rats (l00/sex/exposure concentration) were exposed to 0, 0.1, 1.0, or 10.0 mg/m^3^ atmospherically hydrolyzed titanium tetrachloride for 6 hours/day, 5 days/week, for 104 weeks. Five males and 5 females from each group were sacrificed after 3 and 6 months, 10 animals of each sex were killed after 1 year, and the remaining animals were sacrificed at the end of the second year for gross and microscopic evaluation.

[underlined: Effects noted in study and corresponding doses:] The major health effects of exposure were observed in the respiratory tract of the exposed animals. The primary observation was an increased incidence of irregular breathing and lung noises in the exposed rats that was concentration-dependent. This respiratory effect was present in males (8, 12, 24, and 36%) and females (8, 16, 44, and 41%) exposed to 0, 0.1, 1 .O and 10 mg/m^3^, respectively. The incidence of rhinitis and tracheitis also increased with concentration. In the low-exposure group the incidence of rhinitis was also duration-dependent and ranged from 4.3 to 15% after 1 year of treatment, and from 22 to 64% at the end of the second year. Similar observations were made in the mid- and high-exposure groups. Tracheitis also increased with exposure duration, and to a lesser degree with concentration. The 2 highest groups had increased incidence of tracheitis as early as 3 months, and at the end of 2 years was also increased in the lowest exposure group. The incidences of tracheitis at the end of the 2 years were O-2.5%, 12-20%, 41-49%, 30-44% for the control, low-, mid-, and high-exposure groups, respectively. The 0.1 mg/m^3^ is considered a less serious LOAEL for adverse effects in the tracheobronchial region. Gross pathology and histopathology revealed compound-related changes in the lungs and thoracic lymph nodes of the treated animals. Foci laden with yellow titanium tetrachloride hydrolysis products were present on the lung pleural surface and on the slightly enlarged tracheobronchial lymph nodes in the mid- and highexposure groups. The pulmonary response in these two groups also included the presence of the dustladen macrophages, and the hyperplasia of the alveolar lining. The incidence and severity of alveolar hyperplasia increased with concentration; it was 0% in the control and low-exposure groups, and 32-63% and 92-97% in the mid- and high-exposure groups.

[underlined: Dose and end point used for MRL derivation]: The 0.1 mg/m^3^ is considered a less serious LOAEL for increased incidence of rhinitis and tracheitis.

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 3 for use of a minimal LOAEL
- [X] 3 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] No

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Rats were exposed in stainless steel chambers under dynamic air conditions. Vapors of titanium tetrachloride were generated by passing nitrogen over liquid titanium tetrachloride. Chamber atmospheres were monitored by trapping the solid titanium tetrachloride hydrolysis products on cellulose acetate filters which were analyzed for titanium content. The mass median diameter of the aerosol particles was about 0.5 μm with a geometric standard deviation of about 2 μm. Because the rats were exposed to an aerosol and the critical effect was respiratory, Equation 4-5 in Interim Methods for Development of Inhalation Reference Concentrations (EPA 1990) was used to calculate the HEC (Human Equivalent Concentration). Table H-1 in EPA (1990) was used to determine the ratio of the dose available for uptake from the extrathoracic region of the respiratory system of the experimental animal species to that of humans (RDDR_ET_). The RDDR for the ET region corresponding to a mass median aerodynamic diameter (MMDA) of 0.5 μm with a Sigma g of 2.0 μm is 0.1201. The LOAEL_HEC_ was calculated as follows:

- LOAEL_HEC_ = LOAEL × RDDR_ET_
- = 0.1 × 0.1201
- = 0.01201 mg/m^3^

where:

LOAEL_HEC_ = Human Equivalent concentration of the LOAEL (lowest-observed-adverse effect level)

RDDR_ET_ = Regional Deposited Dose Ratio for Respiratory Effect in the Extrathoracic Region

Thus, the proposed chronic inhalation MRL was derived as follows:

- MRL = LOAEL_HEC_ ÷ UF
- MRL = 0.01201 mg/m^3^ ÷ 90
- MRL =0.0001 mg/m^3^

[underlined: Was a conversion used from intermittent to continuous exposure?] The LOAEL was not adjusted for intermittent exposure because the effects reflect contact irritation.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Several studies in humans lend support to deriving a MRL. A health hazard evaluation of workers employed in a metal reduction factory suggests that exposure to titanium tetrachloride and its hydrolysis products may cause pulmonary impairment (Garabrant et al. 1987; Moseley et al. 1982). The data from those studies support the notion that chronic exposure to titanium tetrachloride may result in restrictive pulmonary changes. However, the concomitant exposure to other chemicals, such as titanium oxide, titanium dichloride, titanium oxychloride, sodium, sodium hydroxide, and sodium oxide prevents a more definitive determination of the role of titanium tetrachloride. Irritation of the upper and lower respiratory tract is observed in humans following acute inhalation exposure to titanium tetrachloride (Park et al. 1984; Ross 1985). The respiratory irritation may lead to cough, wheezing, dyspnea, respiratory distress, and hypoxia. In some cases, impairment of the respiratory function may continue for several weeks following exposure (Park et al. 1984).

Acute inhalation studies in animals also lend support for the MRL derivation. Acute exposure of rats to 1,466, 5,122, 7,529, and 11,492 mg/m^3^ of titanium tetrachloride resulted in wet noses, nasal discharge, dyspnea, and swollen eyelids. (Karlsson et al. 1986). No deaths were found. Histopathology performed 7 days after exposure was essentially normal and revealed only minor lung lesions. The lungs in l/3 and 2/2 animals exposed to 5,122 and 11,492 mg/m^3^, respectively, showed discrete inflammatory residues, coarsened alveolar septa, and sparse accumulation of phagocytes. Rats exposed to 1,200 mg/m^3^ titanium tetrachloride for 30 minutes had severe inflammation of the respiratory epithelium 1 day post-exposure (DuPont 1980). Forty-nine days post-exposure the respiratory epithelium had normal appearance. Rats exposed to 5 mg/m^3^ 6 hours/day, 5 days/week for 4 weeks a mild lung dust cell reaction and increased relative lung weight; both effects were reversible (DuPont 1979). Exposure to >10 mg/m^3^, however, induced bronchiolitis, interstitial pneumonitis, alveolar cell proliferation, hyperplasia of the tracheal epithelium, and collagenized fibrosis. These effects gradually disappeared over a 12-month recovery period. No studies were located regarding reproductive or developmental effects in humans or animals after exposure to titanium tetrachloride by any route.

[underlined: Agency Contact (Chemical Manager)]: Ed Murray