# 8 REGULATIONS AND ADVISORIES

The international, national, and state regulations and guidelines regarding tin and tin compounds in air, water, and other media are summarized in Table 8-1.

ATSDR derived an intermediate-duration oral MRL for inorganic tin of 0.3 mg Sn/kg/day (as stannous chloride) based on a NOAEL of 32 mg/kg/day for hematological effects in rats in a 90-day feeding study (De Groot et al. 1973). An uncertainty factor of 100 was applied to the NOAEL (10 for animal to human extrapolation and 10 for human variability).

ATSDR derived an intermediate-duration oral MRL of 0.005 mg/kg/day for dibutyltin chloride based on a LOAEL of 5 mg/kg/day for immunological effects in rats in a 4–6-week feeding study (Seinen et al. 1977b). An uncertainty factor of 1,000 was applied to the LOAEL (10 for animal to human extrapolation, 10 for the use of a LOAEL, and 10 for human variability).

ATSDR derived an intermediate-duration oral MRL of 0.0003 mg/kg/day for tributyltin oxide based on a NOAEL of 0.025 mg/kg/day for immunological effects in rats in a 4.5–6-month dietary study in rats (Vos et al. 1990). An uncertainty factor of 100 was applied to the NOAEL (10 for animal to human extrapolation and 10 for human variability).

ATSDR derived a chronic-duration oral MRL of 0.0003 mg/kg/day for tributyltin oxide based on a NOAEL of 0.025 mg/kg/day for immunological effects in rats in an 18-month dietary study in rats (Vos et al. 1990). An uncertainty factor of 100 was applied to the NOAEL (10 for animal to human extrapolation and 10 for human variability).

EPA (IRIS 2005) derived an oral reference dose (RfD) of 0.0003 mg/kg/day for tributyltin oxide using a benchmark dose analysis of immunological effects in rats in an 18-month dietary study (Vos et al. 1990). A 10% relative change was chosen as the benchmark response (BMR).

EPA (IRIS 2005) has assigned tributyltin oxide to group D weight-of-evidence classification: not classifiable as to human carcinogenicity, or to a group for which there is “inadequate information to assess carcinogenic potential,” according to updated guidelines (EPA 2003g).

Table 8-1 Regulations and Guidelines Applicable to Tin and Tin Compounds

Agency | Description | Information | | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | No data
WHO | Drinking water guideline | No nurnerical value based | | WHO 1993
WHO | Tin and inorganic tin cornpounds | on low toxicity | | WHO 1993
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air:
ACGIH | TLV (8-hour TWA) | | | ACGIH 2003
ACGIH | Tin (as Sn)
ACGIH | Metal | 2.0 mg/m^3^
ACGIH | Oxide and inorganic cornpounds, except tin hydride | 2.0 mg/m^3^
ACGIH | Organic cornpounds^a^ | 0.1 mg/m^3^
ACGIH | STEL | 0.2 mg/m^3^
NIOSH | REL (10-hour TWA) | | | NIOSH 2003a, 2003b
NIOSH | Tin (as Sn)
NIOSH | Inorganic cornpounds, except tin oxides | 2.0 mg/m^3^
NIOSH | IDLH | 100 mg/m^3^
NIOSH | Organic cornpounds, except cyhexatin^b^ | 0.1 mg/m^3^
NIOSH | IDLH | 25 mg/m^3^
NIOSH | Stannous oxide | 2.0 mg/m^3^
OSHA | PEL (8-hour TWA) for general industry | | | OSHA 2003a; 29 CFR 1910.1000, Table Z-1
OSHA | Tin (as Sn) | | | OSHA 2003a; 29 CFR 1910.1000, Table Z-1
OSHA | Inorganic cornpounds, except oxides | 2.0 mg/m^3^ | | OSHA 2003a; 29 CFR 1910.1000, Table Z-1
OSHA | Organic cornpounds | 0.1 mg/m^3^ | | OSHA 2003a; 29 CFR 1910.1000, Table Z-1
OSHA | PEL (8-hour TWA) for construction industry Tin (as Sn) | | | OSHA 2003c; 29 CFR 1926.55, Appendix A
OSHA | Inorganic cornpounds, except oxides | 2.0 mg/m^3^
OSHA | Organic cornpounds | 0.1 mg/m^3^
OSHA | PEL (8-hour TWA) for shipyard industry | | | OSHA 2003b; 29 CFR 1915.1000
OSHA | Tin (as Sn)
OSHA | Inorganic cornpounds, except oxides | 2.0 mg/m^3^
OSHA | Organic cornpounds | 0.1 mg/m^3^
OSHA | Tin oxide (as Sn) | 15 mg/m^3^
OSHA | Total dust | 15 mg/m^3^
OSHA | Respirable fraction | 5.0 mg/m^3^
USNRC | Occupational values | | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | Oral ingestion for Class D^c^ | [underlined: ALI (μCi)] | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^110^Tin | 4.0×10^3^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^111^Tin | 7.0×10^4^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^113^Tin (LLI wall)^d^ | 2.0×10^3^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^113^Tin | 2.0×10^3^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^117m^Tin (LLI wall)^d^ | 2.0×10^3^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^117m^Tin | 2.0×10^3^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^119m^Tin (LLI wall)^d^ | 3.0×10^3^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^119m^Tin | 4.0×10^3^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^121^Tin (LLI wall)^d^ | 6.0×10^3^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^121^Tin | 6.0×10^3^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^121m^Tin (LLI wall)^d^ | 3.0×10^3^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^121m^Tin | 4.0×10^3^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^123^Tin (LLI wall)^d^ | 5.0×10^2^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^123^Tin | 6.0×10^2^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^123m^Tin | 5.0×10^4^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^125^Tin (LLI wall)^d^ | 4.0×10^2^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^125^Tin | 5.0×10^2^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^126^Tin | 3.0×10^2^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^127^Tin | 7.0×10^3^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^128^Tin | 9.0×10^3^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | Occupational values | | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | Inhalation^e^ for Class D^c^ | [underlined: ALI (μCi)] | [underlined: DAC (μCi/nL)] | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^110^Tin | 1.0×10^4^ | 5.0×10^−6^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^111^Tin | 2.0×10^5^ | 9.0×10^−5^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^113^Tin | 1.0×10^3^ | 5.0×10^−7^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^117m^Tin (bone and surf)^d^ | 1.0×10^3^ | No data | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^117m^Tin | 2.0×10^3^ | 5.0×10^−7^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^119m^Tin | 2.0×10^3^ | 1.0×10^−6^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^121^Tin | 2.0×10^4^ | 6.0×10^−6^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^121m^Tin | 9.0×10^2^ | 4.0×10^−7^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^123^Tin | 6.0×10^2^ | 3.0×10^−7^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^123m^Tin | 1.0×10^5^ | 5.0×10^−5^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^125^Tin | 9.0×10^2^ | 4.0×10^−7^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^126^Tin | 6.0×10^1^ | 2.0×10^−8^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^127^Tin | 2.0×10^4^ | 8.0×10^−6^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^128^Tin | 3.0×10^4^ | 1.0×10^−5^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | Occupational values | | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | Inhalation^e^ for Class W^f^ | [underlined: ALI (μCi)] | [underlined: DAC (μCi/mL)] | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^110^Tin | 1.0×10^4^ | 5.0×10^−6^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^111^Tin | 3.0×10^5^ | 1.0×10^−4^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^113^Tin | 5.0×10^2^ | 2.0×10^−7^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^117m^Tin | 1.0×10^3^ | 6.0×10^−7^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^119m^Tin | 1.0×10^3^ | 4.0×10^−7^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^121^Tin | 1.0×10^4^ | 5.0×10^−6^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^121m^Tin | 5.0×10^2^ | 2.0×10^−7^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^123^Tin | 2.0×10^2^ | 7.0×10^−8^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^123m^Tin | 1.0×10^5^ | 6.0×10^−5^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^125^Tin | 4.0×10^2^ | 1.0×10^−7^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^126^Tin | 7.0×10^1^ | 3.0×10^−8^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^127^Tin | 2.0×10^4^ | 8.0×10^−6^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^128^Tin | 4.0×10^4^ | 1.0×10^−5^ | USNRC 2003; 10 CFR 20, Appendix B
b. Water
EPA | Drinking water standards | No data
c. Food
FDA | Direct food substances affirmed as GRAS in accordance with good manufacturing practices; stannous chloride (anhydrous and dehydrated) | Not to exceed 0.0015% calculated as tin for all food categories | | FDA 2003a; 21 CFR 184.1845
FDA | Food additives permitted for direct addition to food for human consumption; stannous chloride (food additive) may be safely used for color retention in asparagus packed in glass, with lids lined with an inert material | Not to exceed 20 pmm calculated as tin | | FDA 2003b; 21 CFR 172.180
FDA | Indirect food additives; adhesives; bis(tributyltin)oxide | For use as a preservative only | | FDA 2003d; 21 CFR 175.105(c)(5)
FDA | Indirect food additives; polymers; polyurethane resins | Dibutyltin chloride | | FDA 2003e; 21 CFR 177.1680(b)
FDA | Indirect food additives; resinous and polymeric coatings | Stannous chloride | | FDA 2003c; 21 CFR 175.300
FDA | Indirect food additives; rubber articles intended for repeated use; stannous chloride | Activators (total not to exceed 5% by weight of rubber product) | | FDA 2003f; 21 CFR 177.2600(c)(4)
FDA | Substances GRAS in accordance with good manufacturing or feeding practices; stannous chloride | Not to exceed 0.0015% calculated as tin | | FDA 2003g; 21 CFR 582.3845
d. Other
ACGIH | Carcinogenicity classification | A4^g^ | | ACGIH 2003
EPA | Carcinogenicity classification | | | IRIS 2005
EPA | Bis(tributyltin oxide) | D^h^ | | IRIS 2005
EPA | RfD | | | IRIS 2005
EPA | Bis(tributyltin oxide) | 3×10^−^ mg/kg/day
EPA | RfC | | | IRIS 2005
EPA | Bis(tributyltin oxide) | No data
EPA | Community right-to-know; release reporting; effective date of reporting | | | EPA 2003f; 40 CFR 372.65
EPA | Bis(tributyltin)oxide | 01/01/95
EPA | Triphenyltin chloride | 01/01/95
EPA | Emergency release notification | Tin | | EPA 2003c; 40 CFR 355.40
EPA | Extremely hazardous | | | EPA 2003d; 40 CFR 355, Appendix A
EPA | Trimethyltin chloride | | | EPA 2003d; 40 CFR 355, Appendix A
EPA | Reportable quantity | 500 pounds | | EPA 2003d; 40 CFR 355, Appendix A
EPA | Threshold planning quantity | 500/10,000 pounds | | EPA 2003d; 40 CFR 355, Appendix A
EPA | Triphenyltin chloride | | | EPA 2003d; 40 CFR 355, Appendix A
EPA | Reportable quantity | 500 pounds | | EPA 2003d; 40 CFR 355, Appendix A
EPA | Threshold planning quantity | 500/10,000 pounds | | EPA 2003d; 40 CFR 355, Appendix A
EPA | Municipal solid waste landfills; hazardous constituent; tin (total) | [underlined: Method] | [underlined: PQL] | EPA 2003a; 40 CFR 258, Appendix II
EPA | Municipal solid waste landfills; hazardous constituent; tin (total) | 6010 | 40 μg/L | EPA 2003a; 40 CFR 258, Appendix II
EPA | Notification requirements of releases | Tin | | EPA 2003b; 40 CFR 302.6
EPA | Standards for owners and operators of hazardous waste TSD facilities; groundwater monitoring; tin (total) | [underlined: Method] | [underlined: PQL] | EPA 2003e; 40 CFR 264, Appendix IX
EPA | Standards for owners and operators of hazardous waste TSD facilities; groundwater monitoring; tin (total) | 7870 | 8×10^3^ ×g/L | EPA 2003e; 40 CFR 264, Appendix IX
USNRC | Effluent concentrations for Class D^c^ | [underlined: Air (μCi/mL)] | [underlined: Water (μCi/mL)] | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^110^Tin | 2.0×10^−8^ | 5.0×10^−5^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^111^Tin | 3.0×10^−7^ | 1.0×10^−3^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^113^Tin (LLI wall)^d^ | 2.0×10^−9^ | No data | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^113^Tin | No data | 3.0×10^−5^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^117m^Tin | 3.0×10^−9^ | 3.0×10^−5^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^119m^Tin (LLI wall)^d^ | 3.0×10^−9^ | No data | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^19m^Tin | No data | 6.0×10^−5^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^121^Tin (LLI wall)^d^ | 2.0×10^−8^ | No data | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^121^Tin | No data | 8.0×10^−5^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^121m^Tin (LLI wall)^d^ | 1.0×10^−9^ | No data | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^121m^Tin | No data | 5.0×10^−5^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^123^Tin (LLI wall)^d^ | 9.0×10^−10^ | No data | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^123^Tin | No data | 9.0×10^−6^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^123m^Tin | 2.0×10^−7^ | 7.0×10^−4^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^125^Tin (LLI wall)^d^ | 1.0×10^−9^ | No data | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^125^Tin | No data | 6.0×10^−6^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^126^Tin | 8.0×10^−11^ | 4.0×10^−6^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^127^Tin | 3.0×10^−8^ | 9.0×10^−5^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^128^Tin | 4.0×10^−8^ | 1.0×10^−4^ | USNRC 2003; 10 CFR 20, Appendix B
USNRC | Effluent concentrations for Class W^f^ | [underlined: Air (μCi/nL)] | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^110^Tin | 2.0×10^−8^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^111^Tin | 4.0×10^−7^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^113^Tin | 8.0×10^−1C^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^117m^Tin | 2.0×10^−9^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^119m^Tin | 1.0×10^−9^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^121^Tin | 2.0×10^−8^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^121m^Tin | 8.0×10^−1C^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^123^Tin | 2.0×10^−10^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^123m^Tin | 2.0×10^−7^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^125^Tin | 5.0×10^−10^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^126^Tin | 9.0×10^−11^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^127^Tin | 3.0×10^−8^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^128^Tin | 5.0×10^−8^ | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | Release to sewers for Class D^c;^ rnonthly average concentration | | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^110^Tin | 5.0×10^−4^ μCi/rnL | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^111^Tin | 1.0×10^−2^ μCi/rniL | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^113^Tin | 3.0×10^−4^ μCi/3L | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^117m^Tin | 3.0×10^−4^ μCi/3L | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^119m^Tin | 6.0×10^−4^ μCi/3L | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^121^Tin | 8.0×10^−4^ μCi/rnL | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^121m^Tin | 5.0×10^−4^ μCi/3L | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^123^Tin | 9.0×10^−5^ μCi/rniL | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^123m^Tin | 7.0×10^−3^ μCi/3L | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^125^Tin | 6.0×10^−5^ μCi/3L | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^126^Tin | 4.0×10^−5^ μCi/rnL | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^127^Tin | 9.0×10^−4^ μCi/3L | | USNRC 2003; 10 CFR 20, Appendix B
USNRC | ^128^Tin | 1.0×10^−3^ μCi/rniL | | USNRC 2003; 10 CFR 20, Appendix B
[underlined: STATE]
a. Air | No data
b. Water
Florida | Drinking water guideline | | | HSDB 2003
Florida | Tin | 4.2 mg/L
Minnesota | Drinking water guideline | | | HSDB 2003
Minnesota | Tin | 4.0 mg/L
c. Food | No data
d. Other | No data

a Skin notation: refers to the potential significant contribution to the overall exposure by the cutaneous route, including rnucous rnernbranes and the eyes, either by contact with vapors or, of probable greater significance, by direct skin contact with the substance.

b Skin designation

a Class D: refers to the retention (clearance half-tirnes of <10 days) for all cornpounds except those given for W.

c When an ALI is defined by the stochastic dose lirnit, this value alone, is given. When an ALI is deterrnined by the non-stochastic dose lirnit to an organ, the organ or tissue to which the lirnit applies is shown, and the ALI for the stochastic lirnit is shown in parentheses. (Abbreviated organ or tissue designations are used: LLI wall = lower large intestine wall; St. wall = stornach wall; Blad wall = bladder wall; and Bone surf = bone surface.)

d The ALIs and DACs for inhalation are given for an aerosol with an activity rnedian aerodynarnic diarneter (AMAD) of 1 urn and for class D and W of radioactive rnaterial, which refers to their retention (clearance half-tirnes of <10 days and 10-100 days, respectively) in the pulrnonary region of the lung.

e Class W: refers to the retention (clearance half-tirnes of 10-100 days) for sulfides, oxides, hydroxides, halides, nitrates, and stannic phosphate.

f A4: not classifiable as a hurnan carcinogen

g D: not classifiable as to hurnan carcinogenicity

ACGIH = Arnerican Conference of Governrnental Industrial Hygienists; ALI = annual lirnits on intakes; CFR = Code of Federal Regulations; DAC = derived air concentration; EPA = Environrnental Protection Agency; FDA = Food and Drug Adrninistration; GRAS = generally recognized as safe; HSDB = Hazardous Substances Data Bank; IARC = International Agency for Research on Cancer; IDLH = irnrnediately dangerous to life or health; IRIS = Integrated Risk Inforrnation Systern; LLI = lower large intestine; NIOSH = National Institute for Occupational Safety and Health; OSHA = Occupational Safety and Health Adrninistration; PEL = perrnissible exposure lirnit; PQL = practical quantitation lirnit; REL = recornrnended exposure lirnit; RfC = inhalation reference concentration; RfD = oral reference dose; STEL = short-terrn exposure level; TLV = threshold lirnit values; TSD = treatrnent, storage, and disposal; TWA = tirne-weighted average; USNRC = Nuclear Regulatory Cornrnission; WHO = World Health Organization