# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Tin is a naturally occurring element that appears in group 14 (4A) of the periodic table at the boundary between the metals and nonmetals. Tin can form various compounds, both inorganic and organic. Inorganic tin compounds do not contain a tin-carbon bond, whereas organotin compounds contain at least one tin-carbon bond (Kroschwitz and Howe-Grant 1997; Lide 2000). The divalent and tetravalent oxidation states can be designated using the names stannous and stannic, respectively, in the name of the compound. Another commonly encountered nomenclature system, the Stock Oxidation-Number system, denotes the oxidation state in Roman numerals in parentheses following the metal’s name: tin(II) and tin(IV) (Smith 1996). Table 4-1 lists common synonyms and other pertinent identification information for tin and representative inorganic and organic tin compounds.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Tin is a silver-white metal that is malleable and somewhat ductile. It has a highly crystalline structure and exists in two allotropic forms at normal pressures. Gray or Į tin exists below 13.2 °C and has a cubic structure. At 13.2 °C, gray tin is converted to white or β tin, which has a tetragonal structure. In compounds, tin can exist in the +2 or +4 oxidation state. Industrially important organotin compounds include the dimethyltin, dibutyltin, tributyltin, dioctyltin, triphenyltin, and tricyclohexyltin families. Organotin compounds that are industrially important contain tin in the +4 oxidation state (Kroschwitz and Howe-Grant 1997; Lide 2000). Table 4-2 lists important physical and chemical properties of tin and representative inorganic and organic tin compounds.

Table 4-1 Chemical Identity of Tin and Tin Compounds^a^

Characteristic | Tin | Tin(II) chloride | Tin(IV) oxide
Synonyms | Metallic tin; silver matt powder; tin flake | Stannous chloride; tin dichloride; tin protochloride | Stannic oxide; tin oxide; stannic anhydride
Trade name | No data | No data | No data
Chemical formula | Sn | SnCl_2_ | SnO_2_
Chemical structure | Sn | SnCl_2_ | SnO_2_
Identification numbers:
CAS registry | 7440-31-5 | 7772-99-8 | 18282-10-5
NIOSH RTECS | XP7320000^b^ | XP8700000^b^ | XQ4000000^b^
EPA hazardous waste | No data | No data | No data
DOT/UN/NA/ IMCO shipping | No data | No data | No data
HSDB | 5035 | 582 | 5064
NCI | No data | C02722 | No data
EINECS | 231-141-8 | 231-868-0 | 242-159-0

Characteristic | Tin(II) fluoroborate | Tin(II) fluoride | Monomethyltin trichloride
Synonyms | Tetraflurorborate(1-), tin(2+) (2:1); tin bis(tetrafluoroborate) | Stannous fluoride; easygel; fluoristan; Gel-Kam; Gel-Tin | Trichloromethyl stannane; methyltin trichloride
Trade name | No data | No data | No data
Chemical formula | SnB_2_F_8_ | SnF_2_ | CH_3_Cl_3_Sn
Chemical structure | Sn(BF_4_)_2_ | SnF_2_ | [image]
Identification numbers:
CAS registry | 13814-97-6 | 7783-47-3 | 993-16-8
NIOSH RTECS | No data | XQ3450000^b^ | WH8585500^b^
EPA hazardous waste | No data | No data | No data
DOT/UN/NA/ IMCO shipping | No data | No data | No data
HSDB | No data | 783 | No data
NCI | No data | No data | No data
EINECS | 237-487-6 | 231-999-3 | 213-608-8

Characteristic | Dimethyltin dichloride | Trimethyltin chloride | Monobutyltin trichloride
Synonyms | Dichlorodimethyl stannane; Cotin 210 | Chlorotrimethyl stannane; chlorotrimethyltin; trimethylchlorotin | Mono-n-butyltin trichloride; butyltrichloro stannane
Trade name | No data | No data | No data
Chemical formula | C_2_H_6_Cl_2_Sn | C_3_H_9_ClSn | C_4_H_9_Cl_3_Sn
Chemical structure | [image] | [image] | [image]
Identification numbers:
CAS registry | 753-73-1 | 1066-45-1 | 1118-46-3
NIOSH RTECS | WH7245000^b^ | WH6850000^b^ | WH678000^b^
EPA hazardous waste | No data | No data | No data
DOT/UN/NA/ IMCO shipping | No data | No data | No data
HSDB | No data | 6413 | 6073
NCI | No data | No data | No data
EINECS | 212-039-2 | 213-917-8 | 214-263-6

Characteristic | Dibutyltin dichloride | Tributyltin chloride | Monobutyltin hydride
Synonyms | Dibutyltin chloride; dichlorodibutyltin; dichlorodibutylstannane | Chlorotributylstannane; tri-n-butyltin chloride | n-Butyltin; butylstannane; butyltin trihydride
Trade name | No data | No data | No data
Chemical formula | C_8_H_18_Cl_2_Sn | C_12_H_27_ClSn | C_4_H_12_Sn
Chemical structure | [image] | [image] | [image]
Identification numbers:
CAS registry | 683-18-1 | 1461-22-9 | 2406-65-7
NIOSH RTECS | WH7100000^b^ | WH6820000^b^ | No data
EPA hazardous waste | No data | No data | No data
DOT/UN/NA/ IMCO shipping | No data | No data | No data
HSDB | 6071 | No data | No data
NCI | No data | No data | No data
EINECS | 211-670-0 | 215-958-7 | No data

Characteristic | Monobutyltin ion | Dibutyltin hydride | Tributyltin hydride
Synonyms | No data | Di-n-butyltin; dibutylstannane; dibutyltin dihydride | Tributylstannane; tributyltin; Tributylstannic hydride
Trade name | No data | No data | No data
Chemical formula | C_4_H_8_Sn | C_8_H_20_Sn | C_12_H_28_Sn
Chemical structure | [image] | [image] | [image]
Identification numbers:
CAS registry | 78763-54-9 | 1002-53-5 | 688-73-3
NIOSH RTECS | No data | WH6883600^b^ | WH8675000^b^
EPA hazardous waste | No data | No data | No data
DOT/UN/NA/ IMCO shipping | No data | No data | No data
HSDB | No data | No data | 6362
NCI | No data | No data | No data
EINECS | No data | No data | 211-704-4

Characteristic | Tetrabutyltin | Bis(tributyltin) oxide | Triethyltin bromide
Synonyms | Tetrabutylstannane | Lastanox Q; Biomet TBTO; oxybis(tributyltin) | Bromotriethyl-stannane
Trade name | No data | TBTO^c^ | No data
Chemical formula | C_16_H_36_Sn | C_24_H_54_OSn_2_ | C_6_H_15_BrSn
Chemical structure | [image] | [image] | [image]
Identification numbers:
CAS registry | 1461-25-2 | 56-35-9 | 2767-54-6
NIOSH RTECS | WH8605000^b^ | JN8750000^b^ | WH6740000^b^
EPA hazardous waste | No data | No data | No data
DOT/UN/NA/IMCO shipping | No data | No data | No data
HSDB | 6074 | 6505 | No data
NCI | No data | No data | No data
EINECS | 215-960-8 | 200-268-0 | 220-443-5

Characteristic | Triphenyltin | Triphenyltin hydroxide | Triphenyltin chloride
Synonyms | Fentin [ISO]; triphenylstannylium | Fentin hydroxide; hydroxytriphenyl stannane | Chlorotriphenyltin; triphenylchloro-stannane; Aquatin; fentin chloride
Trade name | No data | No data | No data
Chemical formula | C_18_H_15_Sn | C_18_H_16_OSn | C_18_H_15_ClSn
Chemical structure | [image] | [image] | [image]
Identification numbers:
CAS registry | 668-34-8 | 76-87-9 | 639-58-7
NIOSH RTECS | No data | WH8575000^b^ | WH6060000^b^
EPA hazardous waste | No data | No data | No data
DOT/UN/NA/ IMPO shipping | No data | No data | No data
HSDB | No data | 1784 | 6404
NCI | No data | P00260 | No data
EINECS | No data | 200-990-6 | 211-358-4

Characteristic | Mono-n-octyltin trichloride | Di-n-octyltin dichloride | Trioctyltin stannane
Synonyms | Trichlorooctylstannane; n-octyltin trichloride | Dichlorodioctyltin; DOTC; Stannane, dichlorodioctyl- | No data
Trade name | No data | No data | No data
Chemical formula | C_8_H_17_Cl_3_Sn | C_16_H_34_Cl_2_Sn | C_24_H_52_Sn
Chemical structure | [image] | [image] | [image]
Identification numbers:
CAS registry | 3091-25-6 | 3542-36-7 | 869-59-0
NIOSH RTECS | WH8590000^b^ | WH724700^b^ | No data
EPA hazardous waste | No data | No data | No data
DOT/UN/NA/ IMCO shipping | No data | No data | No data
HSDB | No data | No data | No data
NCI | No data | No data | No data
EINECS | 221-435-4 | 222-583-2 | No data

Characteristic | Tri-n-octyltin chloride | Tetra-n-octylstannane
Synonyms | Chlorotrioctyl-stannane | Tetraoctylstannane
Trade name | No data | No data
Chemical formula | C_24_H_51_ClSn | C_32_H_68_Sn
Chemical structure | [image] | [image]
Identification numbers:
CAS registry | 2587-76-0 | 3590-84-9
NIOSH RTECS | WH6855000^b^ | WH8635500^b^
EPA hazardous waste | No data | No data
DOT/UN/NA/ IMCO shipping | No data | No data
HSDB | No data | No data
NCI | No data | No data
EINECS | 219-969-8 | 222-733-7

a All information obtained from HSDB 2003 and ChemID 2003, except where noted.

b RTECS 2003

c Tomlin 1997

CAS = Chemical Abstracts Service; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EINECS = European Inventory of Existing Chemical Substances; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Tin and Tin Compounds^a^

Property | Tin | Tin(II) chloride | Tin(IV) oxide | Tin(II) fluoride
Molecular weight | 118.69 | 189.60 | 150.71 | 156.71
Color | Silver-white | White | White | White
Physical state | Solid | Solid | Solid | Solid
Melting point | 231.9 °C | 246 °C | 1,630 °C | 213 °C
Boiling point | 2,507 °C | 623 °C | Sublimes 1,800–1,900 °C | 850 °C
Density (g/cm^3^) | 7.265 (white tin); 5.769 (gray tin) | 3.90 | 6.95 | 4.57 at 25 °C
Odor | Odorless | Odorless | No data | No data
Odor threshold:
Water | No data | No data | No data | No data
Air | No data | No data | No data | No data
Solubility:
Water | Insoluble | 90 g/100 g water at 20 °C | Insoluble | 30-39% in water at 20 °C
Other solvents | Soluble in hydrochloric acid, sulfuric acid, aqua regia, alkali, slightly soluble in dilute nitric acid | Very soluble in hydrochloric acid; soluble in alcohol, ethyl acetate, glacial acetic acid, sodium hydroxide solution | Insoluble in alcohol, cold acids; slowly soluble in hot concentrated potassium or sodium hydroxide solution | Practically insoluble in ethanol, ether, and chloroformn
Partition coefficients:
Log octanol/water | No data | No data | No data | No data
Log K_oc_ | No data | No data | No data | No data
Vapor pressure | 8×10^−3^ mm Hg at 1,224 °C | 25 mm Hg at 427.9 °C | No data | No data
Henry’s law constant | No data | No data | No data | No data
Autoignition temperature | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data
Flammability limits | No data | No data | No data | No data
Explosive limits | No data | No data | No data | No data

Property | Monomethyltin trichloride | Dimethyltin dichloride | Trimethyltin chloride | Monobutyltin trichloride
Molecular weight | 240.08^b^ | 219.67^b^ | 199.26 | 282.17
Color | Colorless^b^ | Colorless^b^ | Colorless | Colorless
Physical state | Solid^b^ | Solid^b^ | Solid | Liquid
Melting point | 43 °C^b^ | 90 °C (107 °C)^b^ | 37.5 °C | −63 C°
Boiling point | 171 °C^b^ | 185–190 °C^b^ | 154–156 °C | 102 °C at 12 mm Hg
Density (g/cm^3^) | No data | No data | No data | 1.71 at 25 °C
Odor | No data | No data | No data | No data
Odor threshold:
Water | No data | No data | No data | No data
Air | No data | No data | No data | No data
Solubility:
Water | Soluble in cold water^b^ | Soluble in cold water^b^ | Miscible with water | Sparingly soluble in water
Other solvents | Soluble in organic solvents^b^ | Soluble in organic solvents^b^ | Soluble in organic solvents | Soluble in organic solvents
Partition coefficients:
Log octanol/water | No data | No data | No data | No data
Log K_oc_ | No data | No data | No data | No data
Vapor pressure | No data | No data | No data | No data
Henry’s law constant | No data | No data | No data | No data
Autoignition temperature | No data | No data | No data | No data
Flashpoint | 105 °F (40 °C)^c^ | No data | 207 °F (97 °C)^c^ | No data
Flammability limits | No data | No data | No data | No data
Explosive limits | No data | No data | No data | No data

Property | Dibutyltin dichloride | Bis(tributyltin) oxide | Tributyltin chloride | Tributyltin hydride
Molecular weight | 303.85 | 596.11 | 325.49^d^ | 291.09
Color | White | Slightly yellow | Colorless^d^ | No data
Physical state | Solid | Liquid | Liquid^d^ | Liquid
Melting point | 43 °C | <-45 °C^e^ | No data | No data
Boiling point | 135 °C at 10mmHg | 180°C at 2 mm Hg | 145-147 °C at 5 mm Hg^e^ | 112.5-113.5 °C at 8 mm Hg
Density (g/cm^3^) | 1.36 at 24 °C | 1.17 at 25 °C | 1.20^e^ | 1.103 at 20 °C
Odor | No data | Weak odor | No data | No data
Odor threshold:
Water | No data | No data | No data | No data
Air | No data | No data | No data | No data
Solubility:
Water | Insoluble in cold water | 4 mg/L at pH 7, 20 °C | Insoluble in cold water^d^ | No data
Other solvents | Soluble in ether benzene, alcohol | Miscible with organic solvents | Soluble in oxygenated, chlorinated and aromatic solvents^d^ | No data
Partition coefficients:
Log octanol/water | 0.97 | No data | No data | No data
Log K_oc_ | No data | No data | No data | No data
Vapor pressure | 2 mm Hg at 100 °C | 7.5×10^−6^ mm Hg at 20 °C^f^ | No data | No data
Henry’s law constant | No data | No data | No data | No data
Autoignition temperature | No data | No data | No data | No data
Flashpoint | 335 °F (168 °C) | >212 °F (100 °C) | >230 °F (110 °C)^c^ | 104 °F (40 °C)^c^
Flammability limits | No data | No data | No data | No data
Explosive limits | No data | No data | No data | No data

Property | Tetrabutyltin | Triethyltin bromide | Triphenyltin hydroxide | Triphenyltin chloride
Molecular weight | 347.16 | 285.79^b^ | 367.03 | 385.48
Color | Colorless or slightly yellow | Colorless^b^ | White | White
Physical state | Oily liquid | Liquid^b^ | Solid | Solid
Melting point | −97 °C | −13.5 °C^b^ | 119 °C | 103.5 °C
Boiling point | 145 °C at 10 mm Hg | 223-224 °C^b^ | No data | 240 °C at 13.5 mmHg
Density (g/cm^3^) | 1.054 at 20 °C | 1.630 g/mL^b^ | 1.54 at 20 °C | No data
Odor | Distinct, characteristic | No data | Odorless | No data
Odor threshold:
Water | No data | No data | No data | No data
Air | No data | No data | No data | No data
Solubility:
Water | Insoluble in water | Very slightly soluble in coldwater^b^ | 1.2 mg/L at 20 °C | 40 mg/L at 20 °C
Other solvents | Soluble in organic solvents | Soluble in organic solvents^b^ | Slightly soluble in toluene, alcohol | Moderately soluble in organic solvents
Partition coefficients:
Log octanol/water | No data | No data | 3.53 | 4.19
Log K_oc_ | No data | No data | No data | No data
Vapor pressure | No data | No data | 3.53×10^−7^ mm Hg at 25 °C | No data
Henry’s law constant | No data | No data | No data | No data
Autoignition temperature | No data | No data | No data | No data
Flashpoint | 225 °F (107 °C)^c^ | 211 °F (99 °C)^c^ | 211 °F (99 °C)^c^ | No data
Flammability limits | No data | No data | No data | No data
Explosive limits | No data | No data | No data | No data

Property | Tetraoctylstannane
Molecular weight | 571.59^b^
Color | No data
Physical state | No data
Melting point | No data
Boiling point | 268 °C at 10 mm Hg^b^
Density (g/cm^3^) | 0.9605^b^
Odor | No data
Odor threshold:
Water | No data
Air | No data
Solubility:
Water | No data
Other solvents | No data
Partition coefficients:
Log octanol/water | No data
Log K_oc_ | No data
Vapor pressure | No data
Henry’s law constant | No data
Autoignition temperature | No data
Flashpoint | No data
Flammability limits | No data
Explosive limits | No data

a All information obtained from HSDB 2003, except where noted.

b Weast 1980

c Aldrich 2003-2004

d Ashford 1994

e Lewis 1997

f Blunden et al. 1984