# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-32, Atlanta, Georgia 30333.

## Tin Intermediate Oral

MINIMAL RISK LEVEL WORKSHEET

Chemical name: | Tin
CAS number(s): | 7440-31-5
Date: | April 2005
Profile status: | Final Post-Public Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Key to figure: | 13
Species: | Rat

[underlined: Minimal Risk Level]: 0.3 [X] mg/kg/day [ ] ppm

[underlined: Reference]: De Groot AP, Feron VJ, Til HP. 1973. Short-term toxicity studies on some salts and oxides of tin in rats. Food Cosmet Toxicol 11:19–30.4716127

[underlined: Experimental design]: The effect of stannous chloride was studied in male and female Wistar rats (10/sex/dose level) for 13 weeks at dietary levels of 0, 300, 1,000, 3,000, and 10,000 ppm. Using a conversion dietary factor of 0.05 kg food/kg body weight/day and the molecular weight of 118.69 for tin, it can be estimated that the diet provided approximate doses of 0, 9.5, 32, 95, or 315 mg Sn/kg/day. End points monitored included: survival, body weight, food intake, hematology (hemoglobin, hematocrit, total erythrocytes, total and differential leukocytes), serum chemistry (transaminases, alkaline phosphatase, bilirubin), urinalysis, organ weights (nine organs), and gross and microscopic pathology. Tin in the standard diet was not determined, but the concentrations of calcium, phosphorus, iron, copper, and zinc were known. The concentrations of these minerals were consistent with the concentrations in standard rat’s diets, except for the amount of zinc, which was about 50% of that found in the standard diet.

[underlined: Effect noted in study and corresponding doses]: The highest dietary level (315 mg Sn/kg/day) caused reduced food consumption and abdominal distension on week 1. At week 8, loss of body weight occurred in males and females, and one male died. At week 9 another three males died and the group was discontinued. Rats in the 95 mg/kg/day level showed poor appetite and abdominal distension the first 2 weeks; this was associated with decreased food consumption, but they kept growing. At termination, no significant differences in body weights were seen. Food consumption was low also at 32 mg/kg/day, but only on week 1. Hemoglobin concentration was significantly reduced starting at week 4 at 95 and 315 mg/kg/day (about 12 and 20%, respectively) and only at week 4 in 32 mg/kg/day males (3% reduction). Terminal hemoglobin and hematocrit were significantly reduced only in high-dose males (6 and 4%, respectively). Tin had no noticeable effect on osmotic resistance of the erythrocytes or on the number of reticulocytes. Serum alkaline phosphatase was significantly decreased at termination in both sexes but there was no significant effect on transaminases or in bilirubin. Terminal urine samples were unremarkable, as were relative organ weights. Rats from the high-dose group which had to be terminated early showed distended intestines, slight edema of the pancreas, and grayish-brown livers. There was moderate testicular degeneration, severe pancreatic atrophy, spongy white matter in the brain, acute bronchopneumonia, enteritis and liver changes characterized by homogeneous appearance of the liver cell cytoplasm and mild proliferation of the bile duct epithelium. In the other groups at termination, treatment-related effects included bile duct epithelium proliferation and homogeneous cytoplasm at 95 mg/kg/day. The 95 mg/kg/day dose level is considered a minimal LOAEL based on the unknown biological significance of a transient 12% reduction in hemoglobin concentration.

[underlined: Dose and end point used for MRL derivation]: 32 mg/kg/day; decreased hemoglobin concentration.

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] Yes.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:] NA

[underlined: Was a conversion used from intermittent to continuous exposure?] No

[underlined: Other additional studies or pertinent information that lend support to this MRL:] The effects of the administration of stannous chloride, stannous orthophosphate, stannous sulfate, and stannous tartrate at the same dietary levels as above in the diet of rats for 4 weeks are in agreement with the data from the 13-week study (De Groot et al. 1973). The LOAELs for body weight gain, depressed hemoglobin and hematocrit values, and liver histopathology at 4 weeks were seen with the 3,000 ppm diet in males. The NOAEL was the 1,000 ppm diet. With the orthophosphate and tartrate salts, the differences in hemoglobin and hematocrit were not significant with the 3,000 ppm diet, but were significant with the 10,000 ppm diet.

Janssen et al. (1985) reported a LOAEL of 7.9 mg/kg/day for significant decreases in hemoglobin in rats fed a diet containing stannous chloride for 28 days. However, the standard diet contained only 20% of the copper reported for the diet in the De Groot et al. (1973) study. The lower concentrations of these minerals may have made the rats in the Jenssen et al. (1985) study more susceptible to the effects of tin on hematopoiesis. Transient hemolytic anemia was also reported in rabbits administered 10 mg tin/kg/day (as stannous chloride), the only dose level tested, by gavage for 4 months (Chmielnicka et al. 1993). However, no information was provided in that study regarding the trace mineral composition of the diet.

[underlined: Agency Contact (Chemical Manager):] Carolyn Harper, Ph.D.

## Dibutyltin dichloride Intermediate Oral

MINIMAL RISK LEVEL WORKSHEET

Chemical name: | Dibutyltin dichloride
CAS number(s): | 683-18-1
Date: | April 2005
Profile status: | Final Post-Public Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Key to figure: | 28
Species: | Rat

[underlined: Minimal Risk Level]: 0.005 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Seinen W, Vos JG, van Krieken R, . 1977b. Toxicity of organotin compounds. III. Suppression of thymus-dependent immunity in rats by di-n-butyltindichloride and di-n-octyltindichloride. Toxicol Appl Pharmacol 42:213–224.929604

[underlined: Experimental design:] Groups of male and female weanling Wistar rats (5–10/group) were fed diets containing 0, 50, or 150 ppm of the test material (>98% pure) for 4–6 weeks. Based on a body weight of 0.2 kg, it can be estimated that these levels provided doses of dibutyltin dichloride of approximately 0, 5, and 15 mg/kg/day (EPA 1988). End points examined included body weight and parameters of humoral and cellular immune responses. The humoral immune response was assessed by measuring formation of antibodies against SRBC and E. coli lipopolysaccharide. Rats were immunized intraperitoneally with SRBC 5 days before termination of the experiments. The cellular immune response was assessed by examining allograft rejection (rats were grafted at week 7).

[underlined: Effects noted in study and corresponding doses]: Final body weight after 4 weeks of exposure was not significantly altered relative to controls, but it was 28% lower than controls in the high-dose group after 6 weeks of exposure. Allograft rejection time was significantly delayed in the high-dose group relative to controls. In the tests for humoral response, the number of antibody-producing cells per million spleen cells was not affected, but the number per whole spleen was significantly decreased in a dose-related manner. This response was associated with a decreased hemagglutination titer in the high-dose group. The antibody titers against E. coli lipopolysaccharide were slightly but not significantly lower in treated groups than in controls. The dose of 5 mg/kg/day is the study LOAEL based on the reduction in hemagglutinating antibodies against SRBC.

[underlined: Dose and end point used for MRL derivation]: 5.0 mg/kg/day; immunological effects.

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?]

Yes. A food factor of 0.1 kg food/day/kg body weight was calculated using a body weight of 0.2 kg (from study) in an allometric equation (EPA 1988).

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:] NA [underlined: Was a conversion used from intermittent to continuous exposure?] No

[underlined: Other additional studies or pertinent information that lend support to this MRL:] Limited additional information was available for dibutyltin dichloride from intermediate-duration studies. Gaunt et al. (1968) conducted a 90-day dietary general toxicity and histopathology study in rats and found no significant effects other than a slight reduction in hemoglobin with the highest dose tested (5.7 mg/kg/day); no effect was seen at 3.4 mg/kg/day. Although the Gaunt et al. (1968) study defined a NOAEL and, possibly a minimal LOAEL, the immunological alterations reported in the Seinen et al. (1977b) study are preferred as basis for the intermediate-duration oral MRL because of the known immunotoxic properties of dibutyltins (i.e., Seinen et al. 1977a) and tributyltins (dibutyltin is a metabolite of tributyltin; Matsuda et al. 1993; Ueno et al. 1994). In two acute-duration oral studies in rats, serious LOAELs were described at or below the 5 mg/kg/day intermediate-duration LOAEL from Seinen et al. (1977b). In Ema et al. (1991b), 5 mg/kg/day was a serious developmental LOAEL and in Ema and Harazono (2000), 3.8 mg/kg/day was a serious reproductive LOAEL. However, in these two studies, the rats were treated with dibutyltin dichloride by gavage in oil, and the bolus administration may have contributed to the severity of the effects.

[underlined: Agency Contact (Chemical Manager):] Carolyn Harper, Ph.D.

## Tributyltin oxide Intermediate Oral

MINIMAL RISK LEVEL WORKSHEET

Chemical name: | Tributyltin oxide
CAS number(s): | 56-35-9
Date: | April 2005
Profile status: | Final Post-Public Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Key to figure: | 66
Species: | Rat

[underlined: Minimal Risk Level]: 0.0003 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Vos JG, De Klerk A, Krajnc EI, . 1990. Immunotoxicity of bis(tri-n-butyltin)oxide in the rat: effects on thymus-dependent immunity and on nonspecific resistance following long-term exposure in young versus aged rats. Toxicol Appl Pharmacol 105:144–155.2118283

[underlined: Experimental design:] Groups of male Wistar rats were fed a diet containing 0, 0.5, 5, or 50 ppm tributyltin oxide (95.3% pure) for 4.5–6 months. This diet provided approximately 0, 0.025, 0.25, and 2.5 mg/kg/day of the tin compound. Parameters of specific resistance evaluated included IgM and IgG response to ovalbumin and delayed-type hypersensitivity (DTH) response to ovalbumin and tuberculin after 6 months of treatment; resistance to Trichinella spiralis infection after 5.5 months; mitogenic response of thymus and spleen cells after 4.5 months; and surface marker analysis of mesenteric lymph nodes after 6 months. Parameters of nonspecific resistance examined included clearance of Listeria monocytogenes from the spleen after injection at 5 months and natural cell-mediated cytotoxicity of spleen and peritoneal cells after 4.5 months.

[underlined: Effects noted in study and corresponding doses]: Neither body weight nor spleen weight were significantly altered after 4.5 months of treatment, but thymus weight was reduced by 17% relative to controls in the high-dose group. Neither the IgM nor IgG response to ovalbumin and T. spiralis were altered after 5.5 months of exposure. The immunoglobulin E (IgE) responses to T. spiralis, as determined by the passive cutaneous anaphylaxis reaction, were suppressed in a dose-related manner (significant in the mid- and high-dose groups). The DTH reactions to ovalbumin and tuberculin were not significantly altered after 6 months of dosing. There was an increase in the number of larvae T. spiralis in muscle after infection in the mid- and high-dose groups after 5.5 months of exposure to the tin compound. No significant effect was observed on the response of spleen cells to T- and B-mitogens after 4.5 months. The cell surface marker analysis of mesenteric lymph node cells showed a reduction in the relative count of T-lymphocytes and an increase in the percentage of B-lymphocytes in the mid- and high-dose groups after 6 months of treatment. The in vivo clearance of L. monocytogenes was impaired in the high-dose group after 5 months of treatment. Treatment with tributyltin oxide did not induce a consistent effect on the natural killer cell activity of spleen and peritoneal cells after 4.5 months of exposure (decreased in the low- and high-dose groups, and increased in the mid-dose group). Based on the depression of IgE titers and increased T. spiralis in muscle after 5.5 months of exposure to tributyltin oxide, the study LOAEL is 0.25 mg/kg/day and the NOAEL is 0.025 mg/kg/day.

[underlined: Dose and end point used for MRL derivation]: 0.025 mg/kg/day; immunological effects.

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] Yes, conversions were done by the study authors.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:] NA

[underlined: Was a conversion used from intermittent to continuous exposure?] No

[underlined: Other additional studies or pertinent information that lend support to this MRL:] Numerous studies in animals have demonstrated that the main target for some alkyltin compounds, tributyltin among them, is the immune system, particularly the thymus (Boyer 1989; Seinen et al. 1977a, 1977b; Snoeij et al. 1985). Therefore, it is expected that additional intermediate-duration studies, which did not focus on the immune system, identified higher NOAELs. For example, a 4-week dietary study with tributyltin oxide in rats observed slight hematological abnormalities at 0.25 mg/kg/day and hepatic and body weight NOAELs at 1 mg/kg/day (Krajnc et al. 1984). That same study found a 17% in thymus weight at 1 mg/kg/day and a 35% decrease at 4 mg/kg/day. An additional study with tributyltin oxide reported reduced natural killer cell activity in rats at 1 mg/kg/day following 6 weeks of treatment (Van Loveren et al. 1990). In yet another rat study, Verdier et al. (1991) reported slight impairment in host resistance to L. monocytogenes following exposure to tributyltin oxide for 28 days at 5 mg/kg/day, but not at 1 mg/kg/day.

The NOAEL of 0.025 mg/kg/day of Vos et al. (1990) is supported by recent developmental studies with tributyltin chloride that evaluated systemic and immunologic parameters in the offspring of rats exposed to tributyltin chloride in utero (Gds 8-21), through the mother’s milk, and directly as young adults until the age of 90 days (Cooke et al. 2004; Tryphonas et al. 2004). The doses tested were 0, 0.025, 0.25, and 2.5 mg/kg/day. Neither body weights nor food consumption was affected in the dams. No effects were observed on litter size, pup weight at birth, sex ratio, or survival until weaning. Growth of the treated pups after weaning was slightly reduced (<10%) relative to controls and analysis of food consumption and weight gain showed that male pups converted feed into weight gain less effectively than females. No effects were seen on the weights of pup’s brain, kidney or adrenals, but there was a decrease in absolute and relative liver weight in 60-day-old females at 0.025 and 2.5 mg/kg/day, a decrease in absolute and relative liver weight in 90-day-old males at 2.5 mg/kg/day, decrease in absolute spleen weight in 30-day-old males at 2.5 mg/kg/day and in relative spleen weight in 60-day-old females at 2.5 mg/kg/day, and a decrease in relative thymus weight in 60-day-old females at 0.25 and 2.5 mg/kg/day and in absolute thymus weight in 30-day-old males at 2.5 mg/kg/day. No consistent treatment-related gross or microscopic lesions were observed in dams and pups. Clinical chemistry changes of potential biological importance included a decrease in serum amylase in 90-day-old males at 0.25 and 2.5 mg/kg/day and decreased T4, also in 90-day-old males at 2.5 mg/kg/day. Based on the changes in pup’s organ weights and in clinical chemistry parameters, the 0.25 mg/kg/day dose is a LOAEL and 0.025 mg/kg/day a NOAEL. The reduced weight gain of the pups is not considered adverse because the difference with controls was less than 10%.

In the study of immunological parameters (Tryphonas et al. 2004), the only significant change in serum immunoglobulin levels that appeared dose-related was an increase in IgG at 0.25 and 2.5 mg/kg/day in 90-day-old males. Flow cytometric analysis of splenocytes showed a significant increase mean percent and absolute NK cell numbers in high-dose 30-day-old males and females, a decrease in the percentage, but not in absolute numbers of CD4+8+ T cells in 60-day-old females, and an increase in the percentage of NK cells in 90-day-old males. The anti-SRBC IgM response was not affected by exposure to tributyltin. No significant alterations were observed in the lymphoproliferative activity of splenocytes in response to mitogen stimulation. The delayed-type hypersensitivity response (DTH) was not affected in 60-day-old females, but 90-day-old males showed a significant trend toward a decrease in DTH response with increasing doses of tributyltin. The assays for L. monocytogenes infectivity and NK cell activity did not give dose-related responses. Cytokine levels in serum were not affected. Gross examination of lymphoid tissues was unremarkable. The most consistent histological finding was mild to moderate cortical atrophy of the thymus, characterized by decreased numbers of cortical lymphocytes at 2.5 mg/kg/day at all ages.

[underlined: Agency Contact (Chemical Manager):] Carolyn Harper, Ph.D.

## Tributyltin oxide Chronic Oral

MINIMAL RISK LEVEL WORKSHEET

Chemical name: | Tributyltin oxide
CAS number(s): | 56-35-9
Date: | April 2005
Profile status: | Final Post-Public Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Key to figure: | 79
Species: | Rat

[underlined: Minimal Risk Level]: 0.0003 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Vos JG, De Klerk A, Krajnc EI, . 1990. Immunotoxicity of bis(tri-n-butyltin)oxide in the rat: Effects on thymus-dependent immunity and on nonspecific resistance following long-term exposure in young versus aged rats. Toxicol Appl Pharmacol 105:144–155.2118283

[underlined: Experimental design:] Groups of male Wistar rats were fed a diet containing 0, 0.5, 5, or 50 ppm tributyltin oxide (95.3% pure) for 18 months. This diet provided approximately 0, 0.025, 0.25, and 2.5 mg/kg/day of the test material. Parameters of specific resistance evaluated included IgM and IgG response to sheep red blood cells (SRBC) after 16 months; IgM and IgG response to ovalbumin and the delayed-type hypersensitivity (DTH) response to ovalbumin and tuberculin after 15 months of treatment; resistance to T. spiralis infection after 16.5 months; mitogenic response of thymus and spleen cells after 16.5 months; and surface marker analysis of mesenteric lymph nodes after 18 months. Parameters of nonspecific resistance examined included clearance of L. monocytogenes from the spleen after injection at 17 months and natural cell-mediated cytotoxicity of spleen and peritoneal cells after 16 months.

[underlined: Effects noted in study and corresponding doses]: No information was provided regarding body weight or weight of the thymus and spleen at termination. Exposure to tributyltin oxide did not affect the primary IgM or the secondary response to SRBC after 16 months of dosing. Neither the IgM nor IgG response to ovalbumin and T. spiralis were altered after 15 months of treatment, but the IgE responses to T. spiralis, as determined by the passive cutaneous anaphylaxis reaction, was suppressed in a dose-related manner (significant in the mid- and high-dose groups). The DTH reactions to ovalbumin and tuberculin were not significantly altered after 16 months of dosing. There was an increase in the number of larvae T. spiralis in muscle after infection in the mid- and high-dose groups after 16.5 months of exposure to the test material. No significant effect was observed on the response of spleen cells to T- and B-mitogens after 16 months. The cell surface marker analysis of mesenteric lymph node cells showed a reduction in the relative count of T-lymphocytes and an increase in the percentage of B-lymphocytes in the mid- and high-dose groups after 18 months of treatment. The in vivo clearance of L. monocytogenes was impaired in the high-dose group after 17 months of treatment. Treatment with tributyltin oxide for 16 months significantly reduced the natural killer cell activity of spleen and peritoneal cells, but there was no dose-response relationship. Based on the depression of IgE titers and increased T. spiralis in muscle after 16.5 months of exposure to tributyltin oxide, the study LOAEL is 0.25 mg/kg/day and the NOAEL is 0.025 mg/kg/day.

[underlined: Dose and end point used for MRL derivation]: 0.025 mg/kg/day; immunological effects.

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] Yes, conversions were done by the study authors.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:] NA

[underlined: Was a conversion used from intermittent to continuous exposure?] No

[underlined: Other additional studies or pertinent information that lend support to this MRL:] The findings from the intermediate-duration portion of the Vos et al. (1990) study support the longer-term observations. A 2-year bioassay with tributyltin oxide in rats described hepatic, renal, endocrine, and body weight effects with a dose level of 2.1 mg/kg/day and NOAELs for these effects are approximately 0.2 mg/kg/day (Wester et al. 1990). In that study there also were changes in immunoglobulin levels at 2.1 mg/kg/day throughout the study, namely: increase in IgA after 12 and 24 months, decrease in IgG in females after 3 and 13 months, and increase in IgM after 3, 12, and 24 months. No additional chronic-duration studies were located for tributyltin oxide.

[underlined: Agency Contact (Chemical Manager):] Carolyn Harper, Ph.D.