# CHAPTER 8 REFERENCES

* Cited in text

Abbatt JD. 1979. History of the use and toxicity of Thorotrast. Environ Res 18:6–12.387405
*Abdel-Fattah AI, Zhou D, Boukhalfa H, . 2013. Dispersion stability and electrokinetic properties of intrinsic plutonium colloids: Implications for subsurface transport. Environ Sci Technol 47(11):5626–5634.23675849
*Abe H, Kawahara T, Gondou K, . 1999. The reticuloendothelial system and macrophage-monocyte system in Thorotrast patients. Radiat Res 152(6 Suppl):S115–S117.10564950
*Abel KJ, Young JA, Rancitelli LA. 1984. Atmospheric chemistry of inorganic emissions. In: Randerson D, ed. Atmospheric science and power production. Oak Ridge, TN: U.S. Department of Energy, The Technical Information Center, Office of Scientific and Technical Information, 423–465.
ACGIH. 2014. 2014 TLVs and BEIs: Based on the documentation of the threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists. OH241–54.
ACGIH. 2016. In: TLVs and BEIs based on the documentation of the threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
Adelglass JM, Samara M, Cantor JO, . 1980. Thorotrast induced multiple carcinomatosis of the frontal sinus. Bull NY Acad Med 56:453–457.
*Aieta EM, Singley JE, Trussell AR, . 1987. Radionuclides in drinking water: An overview. Am Water Works Assoc J 79:144–152.
*Akkaya R. 2013. Uranium and thorium adsorption from aqueous solution using a novel polyhydroxyethylmethacrylate-pumice composite. J Environ Radioact 120:58–63.23416761
*Albert R, Klevin P, Fresco J, . 1955. Industrial hygiene and medical survey of a thorium refinery. Arch Ind Health 11:234–242.
*Ali M, Kumar A, Pandey BN. 2014. Thorium induced cytoproliferative effect in human liver cell HepG2: Role of insulin-like growth factor 1 receptor and downstream signaling. Chem Biol Interact 211:29–35.24462957
*Anderson RF, Bacon MP, Brewer PG. 1982. Elevated concentrations of actinides in Mono Lake (California, USA). Science 216:514–516.17735740
*Andersson M, Storm HH. 1992. Cancer incidence among Danish Thorotrast-exposed patients. J Natl Cancer Inst 84(17):1318–1325.1495101
*Andersson M, Carstensen B, Storm HH. 1995a. Mortality and cancer incidence after cerebral arteriography with or without Thorotrast. Radiat Res 142(3):305–320.7761581
*Andersson M, Carstensen B, Visfeldt J. 1993a. Leukemia and other related hematological disorders among Danish patients exposed to Thorotrast. Radiat Res 134(2):224–233.8488256
*Andersson M, Jonsson M, Nielsen LL, . 1995b. Mutations in the tumor suppressor gene p53 in human liver cancer induced by α-particles. Cancer Epidemiol Biomarkers Prev 4(7):765–770.8672994
*Andersson M, Juel K, Ishikawa Y, . 1994a. Effects of preconceptional irradiation on mortality and cancer incidence in the offspring of patients given injections of Thorotrast. J Natl Cancer Inst 86(24):1866–1867.7619110
*Andersson M, Juel K, Storm HH. 1993b. Pattern of mortality among Danish Thorotrast patients. J Clin Epidemiol 46(7):637–644.8326349
*Andersson M, Vyberg M, Visfeldt J, . 1994b. Primary liver tumors among Danish patients exposed to Thorotrast. Radiat Res 137(2):262–273.8134550
*Andersson M, Wallin H, Jonsson M, . 1995c. Lung carcinoma and malignant mesothelioma in patients exposed to Thorotrast: Incidence, histology and p53 status. Int J Cancer 63(3):330–336.7591226
*APHA/AWWA/WPCF. 1985. Standard methods for the examination of water and wastewater. 16th ed. Washington, DC: American Public Health Association/American Water Works Association/Water Pollution Control Federation, 162–164.
*Archer VE, Wagoner JK, Lundin FE. 1973. Cancer mortality among uranium mill workers. J Occup Med 15:11–14.4684721
*Arden JW, Gale NH. 1974. Separation of trace amounts of uranium and thorium and their determination by mass spectrometric isotope dilution. Anal Chem 46:687–691.
*Arnold AG, Oelbaum MH. 1980. Thorotrast administration followed by myelofibrosis. Postgrad Med J 56:124–127.7393792
*ASTM. 1986. 1986 annual book of ASTM standards, Vol 11.01 (Section 11). Method D2333-80: Test method for thorium in water. American Society for Testing of Materials, 714–717.
*ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
*ATSDR. 1990a. Toxicological profile for thorium. Atlanta, GA: Agency for Toxic Substances and Disease Registry, U.S. Department of Health and Human Services. Public Health Service
*ATSDR. 1990b. Toxicological profile for radium. Atlanta, GA: Agency for Toxic Substances and Disease Registry, U.S. Department of Health and Human Services. Public Health Service
*ATSDR. 1990c. Toxicological profile for radon. Atlanta, GA: Agency for Toxic Substances and Disease Registry, U.S. Department of Health and Human Services. Public Health Service.
*ATSDR. 1990d. Toxicological profile for uranium. Atlanta, GA: Agency for Toxic Substances and Disease Registry, U.S. Department of Health and Human Services. Public Health Service.
*ATSDR. 2012. Toxicological Profile for Radon. Atlanta, GA: Agency for Toxic Substances and Disease Registry, Department of Health and Human Services. Public Health Service
*ATSDR. 2013. Toxicological Profile for Uranium. Atlanta, GA: Agency for Toxic Substances and Disease Registry, Department of Health and Human Services. Public Health Service
*ATSDR. 2017. Thorium. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention. http://www.atsdr.cdc.gov/SPL/resources/index.html. October 6, 2017.
*Baeza A, Guillen J. 2006. Influence of the soil bioavailability of radionuclides on the transfer of uranium and thorium to mushrooms. Appl Radiat Isot 64(9):1020–1026.16723237
*Baglan N, Cossonnet C, Ritt J. 2001. Determination of 232Th in urine by ICP-MS for individual monitoring purposes. Health Phys 81(1):76–81.11414627
Ballou JE, Hursh JB. 1972. The measurement of thoron in the breath of dogs administered inhaled or injected ThO2. Health Phys 22:155–159.5014870
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Baserga R, Yokoo H, Henegar GC. 1960. Thorotrast induced cancer in man. Cancer 13:1021–1031.13687574
Baxter PJ, Anthony PP, Macsween RNM, . 1980a. Angiosarcoma of the liver: Annual occurrence and aetiology in Great Britain. Br J Ind Med 37:213–221.7191719
*Baxter PJ, Langlands AO, Anthony PP, . 1980b. Angiosarcoma of the liver: A marker tumour for the late effects of Thorotrast in Great Britain. Br J Cancer 41:446–453.7190017
*Becker N, Liebermann D, Wesch H, . 2008. Mortality among Thorotrast-exposed patients and an unexposed comparison group in the German Thorotrast study. Eur J Cancer 44(9):1259–1268.18395438
Behari JR, Tandon SK, Mathur AK, . 1975. Histological and biochemical alterations in rat’s liver and kidney induced by thorium nitrate. Arh Hig Rada Toksikol 26:267–274.1225262
*BEIR III. 1980. The effects on populations of exposure to low levels of ionizing radiation. Committee on the Biological Effects of Ionizing Radiations, National Research Council. Washington, DC: National Academy Press.
*BEIR IV. 1988. Health risks of radon and other internally deposited alpha-emitters. Committee on the Biological Effects of Ionizing Radiations, National Research Council. Washington, DC: National Academy Press, 245–275.
*BEIR V. 1990. Health effects of exposure to low levels of ionizing radiation. Committee on the Biological Effects of Ionizing Radiations, National Research Council. Washington, DC: National Academy Press.
*Beretka J, Mathew PJ. 1985. Natural radioactivity of Australian building materials, industrial wastes and by-products. Health Phys 48:87–95.3967976
*Bernabee RP. 1983. A rapid method for the determination of americium, curium, plutonium and thorium in biological and environmental samples. Health Phys 44:688–692.6853198
*Bigu J. 1985. Radon daughter and thoron daughter deposition velocity and unattached fraction under laboratory-controlled conditions and in underground uranium mines. J Aerosol Sci 16:157–165.
*Bodek I, Lyman WJ, Reehl RF, ., eds. 1988. Environmental inorganic chemistry: Properties, processes and estimation methods. SETAC Special Publication Series, New York, NY: Pergamon Press, 9.2–19.
*Boecker BB. 1963. Thorium distribution and excretion studies. Am Ind Hyg Assoc J 24:155–163.
*Boecker BB, Thomas RG, Scott JK. 1963. Thorium distribution and excretion studies. II. General patterns following inhalation and the effect of the size of the inhaled dose. Health Phys 9:165–176.
*Boniforti R. 1987. Lanthanides, uranium, and thorium as possible simulators of the behavior of transuranics in the aquatic environment. Sci Total Environ 64:181–189.
*Boone IU, Rogers BS, White DC, . 1958. Toxicity excretion and tissue distribution of ionium (Th-230) in rats. Am Ind Hyg Assoc J 19:285–295.13571146
*Bowen JH, Woodward BH, Mossler JA, . 1980. Energy dispersive x-ray detection of thorium dioxide. Arch Pathol Lab Med 104:459–461.6932191
Brody H, Cullen M. 1957. Carcinoma of the breast seventeen years after mammography with Thorotrast. Surgery 42:600–606.13467622
Brown WM, Buckton KE, Langlands AO, . 1967. The identification of lymphocyte clones with chromosome structural aberrations in irradiated men and women. Int J Radiat Biol 13:155–169.
*Bruenger FW, Miller SC, Lloyd RD. 1991. A comparison of the natural survival of beagle dogs injected intravenously with low levels of 239Pu, 226Ra, 228Ra, 228Th, or 90Sr. Radiat Res 126(3):328–337.2034790
Brues AM. 1979. The long term follow-up of radium dial painters and thorium workers. Med Bases Radiat Accident Prep:441–450.
*Buckton KE, Langlands AO. 1973. The Edinburgh Thorotrast series - report of a cytogenetic study. In: 3rd International Meeting: Toxicity of Thorotrast, April 25-27, 1973. RISO Report No. 294:114–125.
*Bulman RA. 1976. Concentration of actinides in the food chain. United Kingdom: National Radiological Protection Board. NRPB-R-44.
Burnett WC. n.d. US-New Zealand cooperative research into the development and application of a new method for separation of uranium-series isotopes. Washington, DC: National Science Foundation, Division of International Programs.
Cantor JO, Adelglass J, Cerreta JM, . 1981. Collision tumor of the frontal sinus: Evidence of prior intrasinus instillation of Thorotrast. Laryngoscope 91:798–803.6262586
*Carpenter R, Beasley TM, Zahnie D, . 1987. Cycling of fallout (plutonium, americium-241, cesium-137) and natural (uranium, thorium, lead210) radionuclides in Washington continental slope sediments. Geochim Cosmochim Acta 51:1897–1921.
*Carvalho FP, Oliveira JM, Malta M. 2014. Exposure to radionuclides in smoke from vegetation fires. Sci Total Environ 472:421–424.24295758
CAS. 1990. Chemical Abstract Service. February 14, 1989.
*Chandramouleeswaran S, Ramkumar J, Sudarsan V, . 2011. Boroaluminosilicate glasses: Novel sorbents for separation of Th and U. J Hazard Mater 198:159–164.22061443
*Chen SB, Zhu YG, Hu QH. 2005. Soil to plant transfer of 238U, 226Ra and 232Th on a uranium mining-impacted soil from southeastern China. J Environ Radioact 82(2):223–236.15878419
Chen XA, Cheng YE, Xiao H, . 2003. A 20-year follow-up study on the effects of long-term exposure to thorium dust. Chin Med J 116(5):692–694.12875682
Chen XA, Cheng YE, Xiao H, . 2004. Health effects following long-term exposure to thorium dusts: A twenty-year follow-up study in China. Radioprotection 39(4):525–533.
*Chong CS, Chong HY, Fun HK, . 1985. Gamma radioactivity level in Sn slag dumps. Health Phys 49:1008–1010.4066326
*Christensen P, Madsen MR, Jensen OM. 1983. Latency of Thorotrast-induced renal tumours. Survey of the literature and a case report. Scand J Urol Nephrol 17:127–130.6867617
*Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
*Clifton RJ, Farrow M, Hamilton EI. 1971. Measurements of Th-232 in normal and industrially exposed humans. Ann Occup Hyg 14:303–308.
*Cochran JK. 1984. The fates of uranium and thorium decay series nuclides in the estuarine environment. Estuary Filter, 179–220.
*Coles DG, Ragaini RC, Ondov JM, . 1979. Chemical studies of a stack fly ash from a coal-fired power plant. Environ Sci Technol 13:455–459.
*Conibear SA. 1983. Long term health effects of thorium compounds on exposed workers: The complete blood count. Health Phys 44(Suppl 1):231–237.6862902
*Coorey KD. 1983. Thorotrast granuloma of the neck with local complications. Med J Aust 2:580–581.6633394
*Costa-Ribeiro C, Barcinski MA, Figueiredo N, . 1975. Radiobiological aspects and radiation levels associated with the milling of monazite sand. Health Phys 28:225–231.1112723
*Cothern CR. 1987. Development of regulations for radionuclides in drinking water. In: Graves B ed. Conference: NWWA, April 7-19, Somerset, NJ. Michigan: Lewis Publishers, 1–11.
*Cothern CR, Lappenbusch WL, Michel J. 1986. Drinking water contribution to natural background radiation. Health Phys 50:33–47.3943972
*Cottrell WD, Haywood, FF, Witt, . 1981. Radiological survey of the Shpack Landfill, Norton, Massachusetts. Report DOE/EV-ORNL-5799, 0005/31. Oak Ridge, TN: Oak Ridge National Laboratory.
Dahlgren S. 1961. Thorotrast tumors: A review of the literature and report of two cases. Acta Pathol Microbial Scand 53:147.
*Dalheimer AR, Kaul A, Said MD. 1988. Analysis of tissue samples containing colloidal thorium dioxide (Thorotrast) or zirconium dioxide (Zirconotrast): Radiochemical preparation and alpha-spectrometry. Sci Total Environ 70:335–353.3363335
*Dams R, Robbins JA, Rahn KA, . 1970. Nondestructive neutron activation analysis of air pollution particles. Anal Chem 42:861–867.5431523
*da Motta LC, da Silva Horta J, Tavares MH. 1979. Prospective epidemiological study of Thorotrast exposed patients in Portugal. Environ Res 18:152–172.499134
*Dang HS, Jaiswal DD, Sunta CM. 1986. Daily intake of thorium by an Indian urban population. Sci Total Environ 57:73–77.3810149
*Dang HS, Jaiswal DD, Sunta CM, . 1989. A sensitive method for the determination of Th in body fluids. Health Phys 57(3):393–396.2777544
*da Silva Horta J. 1956. Late lesions in man caused by colloidal thorium dioxide (Thorotrast). Arch Pathol 62:403–418.
*da Silva Horta J. 1967a. Late effects of Thorotrast on the liver and spleen, and their efferent lymph nodes. Ann NY Acad Sci 145:675–699.
*da Silva Horta J. 1967b. Effects of colloidal thorium dioxide extravasates in the subcutaneous tissues of the cervical region in man. Ann NY Acad Sci 145:776.5239251
da Silva Horta J, Moura NJ. 1979. Movement of Thorotrast aggregates in the bone marrow. Environ Res 18:184–191.499136
*da Silva Horta J, Cayolla Da Motta L, Tavares MH. 1974. Thorium dioxide effects in man. Epidemiological clinical and pathological studies (experience in Portugal). Environ Res 8:131–159.4455502
*Davis MW. 1985. Radiological significance of thorium processing in manufacturing. Report. INFO-0150.
*Dejgaard A, Krogsgaard K, Jacobsen M. 1984. Veno-occlusive disease and peliosis of the liver after Thorotrast administration. Virchows Archiv Pathol Anat 403:87–94.
*DOE. 2014a. Calculation of slope factors and dose coefficients. Oak Ridge, TN: U.S. Department of Energy. Oak Ridge National Laboratory. ORNL/TM-2013/00. https://epa-prgs.ornl.gov/radionuclides/SlopesandDosesFinal.pdf. June 20, 2018.
DOE. 2014b. [Appendices to:] Calculation of slope factors and dose coefficients. Oak Ridge, TN: U.S. Department of Energy. Oak Ridge National Laboratory. ORNL/TM-2013/00. https://epa-prgs.ornl.gov/radionuclides/SlopesandDosesMasterTableFinal.pdf. June 20, 2018.
*DOE. 2016a. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29 for Chemicals of Concern - May 2016. Oak Ridge, TN: U.S. Department of Energy. https://energy.gov/ehss/protective-action-criteria-pac-aegls-erpgs-teels-rev-29-chemicals-concern-may-2016. March 2, 2017.
*DOE. 2016b. Table 3: Protective Action Criteria (PAC) Rev. 29 based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. May 2016. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/teel/Revision_29_Table3.pdf. February 28, 2017.
*dos Santos Silva I, Jones M, Malveiro F, . 1999. Mortality in the Portuguese Thorotrast study. Radiat Res 152(6 Suppl):S88–S92.10564944
*dos Santos Silva I, Malveiro F, Jones ME, . 2003. Mortality after radiological investigation with radioactive Thorotrast: A follow-up study of up to fifty years in Portugal. Radiat Res 159(4):521–534.12643797
Dougherty JH, Rosenblatt LS. 1971. Long term hematological effects of internal emitters in beagles. Radiat Res 48:319–331.5115771
*Dougherty TF, Stover BJ, Dougherty JH, . 1962. Studies of the biological effects of Ra^226^ Pu^239^ Ra^228^(MsTH_1_),Th^228^(RdTh), and Sr^90^ in adult beagles. Radiat Res 17:625–681.
*Downs WL, Scott KJ, Maynard EA, . 1959. Studies on the toxicity of thorium nitrate. Report UR561, Contract W-7401-eng-49. Atomic Energy Project, University of Rochester, Rochester, NY, 1–35.
Dudley RA. 1978. Bone irradiation in Thorotrast cases: Results of measurements at IAEA. Health Phys 35: 103–112.721478
*Early P, Razzak M, Sodee D. 1979. Nuclear medicine technology, 2nd ed. St. Louis: C.V. Mosby Company.
*Edgington DN. 1967. The estimation of thorium and uranium at the submicrogram level in bone by neutron activation. Int J Appl Radiat Isot 18:11–18.6015745
*Eichholz G. 1982. Environmental aspects of nuclear power. Ann Arbor, MI: Ann Arbor Science.
Einck-Rosskamp P, Rajewsky B, Stahlhofen W. 1969. Cross placental passage of radium-228 and its daughters after intravenous injection of colloidal thorium. AEC Symp Ser 17:121–135.
*Ellis LC, Berliner DL. 1967. The effects of ionizing radiations on endocrine cells. Radiat Res 32:520–537.6065247
*EPA. 1980. U.S. Environmental Protection Agency. Guidelines and methodology used in the preparation of health effect assessment chapters of the consent decree water criteria documents. Fed Regist 45:79347–79357.
*EPA. 1984. Background information document (integrated risk assessment). Final rules for radionuclides. Vol I. Washington, DC: U.S. Environmental Protection Agency, Office of Radiation Programs. EPA5201840221.
*EPA. 1987. Radiation protection guidance to federal agencies for occupational exposure; approval of Environmental Protection Agency recommendations. Fed Regist 52:2823–2834.
*EPA. 1988a. Technological approaches to the cleanup of radiologically contaminated superfund sites. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. EPA540288002.
*EPA. 1988b. Limiting values of radionuclide intake and air concentration and dose conversion factors for inhalation, submersion, and ingestion. Federal Guidance Report No. 11. Washington, DC: U.S. Environmental Protection Agency, Office of Radiation Programs. EPA520188020.
*EPA. 1988c. Maximum contaminant levels for radium-226, radium-228, and gross alpha-particle radioactivity in community water systems. 40 CFR 141.15. Fed Regist 533.
*EPA. 1989a. Interim Methods for Development of Inhalation References Doses. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA600888066F.
*EPA. 1989b. Reportable quantity adjustment-radionuclides; Final rules. Fed Regist 54:22524–22543.
*EPA. 1993. Federal Guidance Report No. 12. External exposure to radionuclides in air, water, and soil. U.S. Environmental Protection Agency. EPA402R93081. https://www.epa.gov/sites/production/files/2015-05/documents/402-r-93-081.pdf. December 14, 2017.
*EPA. 1999. Federal Guidance Report No. 13: Cancer risk coefficients for environmental exposure to radionuclides. U.S. Environmental Protection Agency. EPA402R99001. https://www.epa.gov/radiation/federal-guidance-report-no-13-cancer-risk-coefficients-environmental-exposure. December 14, 2017.
*EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency, Office of Environmental Information. EPA260B05001.
*EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. September 7, 2017.
*EPA. 2012. Drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA822S12001. https://www.epa.gov/sites/production/files/2015-09/documents/dwstandards2012.pdf. April 25, 2013.
*EPA. 2014. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water.
*EPA. 2016. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2016-03/documents/compiled_aegl_update_.pdf. September 8, 2017.
*Ettenhuber E, Lehmann R. 1986. The collective dose equivalent due to the naturally occurring radionuclides in building materials in the German Democratic Republic. Part I: External exposure. Health Phys 50:49–56.3943973
*Faber M. 1973. Effect of Thorotrast enriched with thorium-230. Danish Atomic Energy Commission, In: 3rd International Meeting: Toxicity of Thorotrast, April 25-27, 1973. RISO Report No. 294:294–302.
*Faber M. 1979. 28 years of continuous follow-up of patients injected with Thorotrast for cerebral angiography. Environ Res 18:37–43.499142
*Falk H, Telles NC, Ishak KG. 1979. Epidemiology of Thorotrast induced hepatic angiosarcoma in the USA. Environ Res 18:67–73.
*Farid I, Conibear SA. 1983. Hepatic function in previously exposed thorium refinery workers as compared to normal controls from the health and nutrition survey. Health Phys 44(Suppl 1):221–230.
*FDA. 2013. Everything Added to Food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://www.accessdata.fda.gov/scripts/fcn/fcnnavigation.cfm?rpt=eafuslisting. January 8, 2014.
*FDA. 2017. Subpart B - Requirements for specific standardized beverages. Bottled water. U.S. Food and Drug Administration. Code of Federal Regulations 21 CFR 165.110 https://www.gpo.gov/fdsys/pkg/CFR-2017-title21-vol2/pdf/CFR-2017-title21-vol2-sec165-110.pdf. September 7, 2017.
FEDRIP. 1990. Federal Research in Progress. Databank. July 24, 1990.
*Filer TD. 1970. Fluorometric determination of submicrogram quantities of thorium. Anal Chem 42:1265–1267.5458224
*Fischer P, Golob E, Kunze-Muehl E. 1967. Chromosomal aberrations in thorium dioxide patients. Ann NY Acad Sci 145:759–766.5239249
*Fisenne IM, Perry PM, Decker KM, . 1987. The daily intake of 234,235,238U 228,230,232Th, and 226,228Ra by New York City residents. Health Phys 53:357–363.3654223
*Fisher DR, Jackson PO, Brodaczynski GG, . 1983. Level of 234U, 238U and 230Th in excreta of uranium mill crushermen. Health Phys 45:617–630.6885471
*Fisher NS, Teyssie JL, Krishnaswami S, . 1987. Accumulation of thorium, lead, uranium, and radium in marine phytoplankton and its geochemical significance. Limnol Oceanogr 32:131–142.
Fishman EK, Gayler BW, Kashima HK, . 1984. Computed tomography in the evaluation of cervical Thorotrast granuloma. J Comput Assist Tomogr 8:224–228.6707269
*Frank AL. 1980. Diseases associated with exposure to metals-thorium. In: Last JMM-R, ed. Public health and preventive medicine. 11th ed. New York, NY: Appleton-Century-Crofts, 681–682.
*FRC. 1960. Federal Radiation Council. Radiation protection guidance for federal agencies. Fed Regist 60:4402–4403.
*Fried JF, Schubert J. 1961. Effect of chelating agent administration on the removal of monomeric and polymeric thorium. Radiat Res 15:227–235.13701919
*Fruchter JS, Robertson DE, Evans JC, . 1980. Mount St. Helen’s ash from the 18 May 1980 eruption: Chemical, physical, mineralogical, and biological properties. Science 29:1116–1125.
*Gafvert T, Pagels J, Holm E. 2003. Thorium exposure during tungsten inert gas welding with thoriated tungsten electrodes. Radiat Prot Dosimetry 103(4):349–357.12797558
*Gaidova ES, Syao-Shan Y. 1970. Morphological changes in the lungs and other organs in rats on intratracheal administration of thorium dioxide. In: Letavet AA, Kurlyandskaya EB, eds. The toxicology of radioactive substances, Vol. 4. New York: Pergamon Press, 66–82.
*Gallegos G. 1995. Surveillance monitoring of soils for radioactivity: Lawrence Livermore National Laboratory 1976 to 1992. Health Phys 69(4):487–493.7558838
*Garten CT Jr. 1978. A review of parameter values used to assess the transport of plutonium, uranium and thorium in terrestrial food chains. Environ Res 17:437–452.400973
*Gilbert GE, Casella VR, Bishop CT, . 1985. Isotopes of uranium and thorium, lead-210, and polonium-210 in the lungs of coal miners of Appalachia and the lungs and livers of residents of central Ohio. Energy Res Abstr 11:4090.
*Gilman JPW, Ruckerbauer GM. 1962. Metal carcinogenesis. I. Observations on the carcinogenicity of a refinery dust, cobalt oxide and colloidal thorium dioxide. Cancer Res 22:152–156.13898692
*Glover SE, Traub RJ, Grimm CA, . 2001. Distribution of natural thorium in the tissues of a whole body. Radiat Prot Dosimetry 97(2):153–160.11843357
*Golchert NW, Iwami FS, Sedlet J. 1980. Determination of actinides in soil. In: Lyon WS, ed. Radioelement analysis: Progress and problems. 23rd conference: Analytical Chemistry in Energy Technology, Gatlinburg, TN, October 9-11, 1979. Ann Arbor, MI: Ann Arbor Science Publishers, Inc., 215–222.
*Gonzalez-Vasconcellos I, Domke T, Kuosaite V, . 2011. Differential effects of genes of the Rb1 signalling pathway on osteosarcoma incidence and latency in alpha-particle irradiated mice. Radiat Environ Biophys 50(1):135–141.21063720
Goren AD, Harley N, Eisenbud L, . 1980. Clinical and radiobiologic features of Thorotrast induced carcinoma of the maxillary sinus. Oral Surg Oral Med Oral Pathol 49:237–242.6928309
*Gossner W. 1982. Thorium II: Biological effects of thorium. In: Galle P, Masse R, eds. Radionuclide metabolism and toxicity symposium proceedings. Masson Publications, 273–280.
*Grampa G. 1967. Liver distribution of colloidal thorium dioxide and development of liver epithelial tumors in rats. Ann NY Acad Sci 145:738.5239246
*Grampa G. 1971. Radiation injury with particular reference to Thorotrast. Pathol Ann 6:147–169.
*Greenberg RR, Kinston HM. 1982. Simultaneous determination of 12 trace elements in estuarine and sea water using pre-irradiation chromatography. In: 1981 International Conference: Modern trends in activation analysis, Part 3, Toronto, Ontario, Canada, June 15-16, 1981. J Radioanal Chem 71:147–168.
*Gridgeman NT. 1971. Methods of assay of the relative toxicity of certain bone seeking radionuclides. Radiat Res 48:291–302.5286614
*Guimaraes JP, Lamerton LF. 1956. Further experimental observations on the late effects of Thorotrast administration. Br J Cancer 10:527.13396103
*Guimaraes JP, Lamerton LF, Christensen WR. 1955. The late effects of Thorotrast administration: A review and experimental study. Br J Cancer 9:253.13239953
*Gunning C, Scott AG. 1982. Radon and thoron daughters in housing. Health Phys 42:527–528.6282785
*Hall RH, Stroud CA, Scott JK, . 1951. Acute toxicity of inhaled thorium compounds. Atomic Energy Project, University of Rochester, Rochester, NY. Report No. UR-190.
*Hallegot PH, Galle P. 1988. Microanalytical study of thorium 232 deposits in bone marrow and liver. Radiat Environ Biophys 27:67–78.3353495
*Hamilton EI. 1971. The relative radioactivity of building materials. Am Ind Hyg Assoc J 32:398–403.5089835
+Hannibal L. 1982. On the radiological significance of inhaled uranium and thorium ore dust. Health Phys 42:367–371.7068396
*Hare D, Tolmachev S, James A, . 2010. Elemental bio-imaging of thorium, uranium, and plutonium in tissues from occupationally exposed former nuclear workers. Anal Chem 82(8):3176–3182.20218581
*Harley NH, Fisenne IM. 1990. Distribution and alpha radiation dose from naturally occurring U, Th, and Ra in the human skeleton. Health Phys 58(4):515–518.2323933
*Harley NH, Pasternack BS. 1979. Potential carcinogenic effects of actinides in the environment. Health Phys 37:291–300.229088
*Harmsen K, De Haan FAM. 1980. Occurrence and behaviour of uranium and thorium in soil and water. Neth J Agric Sci 28:40–62.
*Harrist TJ, Schiller AL, Trelstad RL, . 1979. Thorotrast-associated sarcoma of bone: A case report and review of the literature. Cancer 44:2049–2058.389408
*Hart DR, McKee PM, Burt AJ, . 1986. Benthic community and sediment quality assessment of Port Hope Harbor, Lake Ontario (Canada). J Great Lakes Res 12:206–220.
*Hawley GG, ed. 1981. The condensed chemical dictionary. 10th ed. New York, NY: Van Nostrand Reinhold, 881, 1021–1022.
*Hedrick JB. 1985. Thorium. Preprint from Bulletin 675: Mineral facts and problems, 1985 ed. Washington, DC: Bureau of Mines, U.S. Department of the Interior.
*Hedrick JB. 1987. Thorium. Preprint from the 1987 Bureau of Mines mineral yearbook. Washington, DC: Bureau of Mines, U.S. Department of the Interior.
Hemphill FM, Hesselgren RD. 1971. Thorotrast quantities and whole body counts. Health Phys 21:85–89.5000409
*Hendee W. 1973. Radioactive isotopes in biological research. New York, NY: John Wiley and Sons.
*Hewson GS, Fardy JJ. 1993. Thorium metabolism and bioassay of mineral sands workers. Health Phys 64(2):147–156.8449708
*Heyerdahl H, Abbas N, Brevik EM, . 2012. Fractionated therapy of HER2-expressing breast and ovarian cancer xenografts in mice with targeted alpha emitting 227Th-DOTA-p-benzyl-trastuzumab. PLoS ONE 7(8):e42345.22879947
*Heyerdahl H, Krogh C, Borrebaek J, . 2011. Treatment of HER2-expressing breast cancer and ovarian cancer cells with alpha particle-emitting 227Th-trastuzumab. Int J Radiat Oncol Biol Phys 79(2):563–570.21195878
*Hirose K. 1988. Determination of thorium isotopes in seawater by using preconcentration of thorium-XO complexes on XAD-2 resin. J Radioanal Nucl Chem-Lett 127:199–207.
*Hirose K, Sugimura Y. 1987. Thorium isotopes in the surface air of the western north Pacific Ocean. J Environ Radioact 5:459–475.
*Hobbs C, McClellan RO. 1986. Radiation and radioactive materials. In: Klassen CD, Amdur MO, Doull J, eds. Casarett and Doull’s Toxicology, 3rd ed. New York, NY: Macmillan Publishing Co., Inc., 497–530.
*Hodge HC, Maynard EA, Leach LJ. 1960. The chemical toxicity of thorium dioxide following inhalation by laboratory animals. University of Rochester Atomic Energy Project. Report UR-562. University of Rochester, Rochester, NY, 1–33.
*Hodgson SA, Stradling GN, Hodgson A, . 2003. Biokinetics and assessment of intake of thorium dioxide. Radiat Prot Dosimetry 105(1–4):115–118.14526939
*Hoegerman SF, Cummins HT. 1983. Chromosome damage in peripheral lymphocytes from American thorium workers. Health Phys 44(Suppl 1):365–371.6862913
*HSDB. 1990. Hazardous Substances Data Bank. National Library of Medicine, Washington, DC. February 14, 1989.
*Hu SJ, Kandaiya S. 1985. Radium-226 and 232Th concentration in Amang. Health Phys 49:1003–1007.4066325
*Hu SJ, Chong CS, Subas S. 1981. U-238 and Th-232 in Cassiterites samples and Amang by-products. Health Phys 40:248–250.7216807
*Hu SJ, Koo WK, Tan KL. 1984. Radioactivity associated with Amang upgrading plants. Health Phys 46:452–455.6693279
*Huh C-A, Bacon MP. 1985. Determination of thorium concentration in seawater by neutron activation analysis. Anal Chem 57:2138–2142.
*Huh C-A, Zahnle DL, Small LF, . 1987. Budgets and behaviors of uranium and thorium series isotopes in Santa Monica basin (California, USA) sediments. Geochim Cosmochim Acta 51:1743–1754.
*Humphreys JA, Priest ND, Ishikawa Y. 1998. Thorotrast distribution in monkey bone marrow at early and late times after injection. Health Phys 74(4):442–447.9525417
*Hunter KA, Hawke DJ, Choo LK. 1988. Equilibrium adsorption of thorium by metal-oxides in marine electrolytes. Geochim Cosmochim Acta 52:627–636.
*Hursh JB, Steadman LT, Looney WB, . 1957. The excretion of thorium and thorium daughters after Thorotrast administration. Acta Radiol 47:481–498.13444059
*Hyman C, Paldino RL. 1967. Influence of sex hormones and tissues on colloidal thorium dioxide distribution and effects in rabbits. Ann NY Acad Sci 145:576–584.5239234
*IAEA. 2014. Radiation protection and safety of radiation sources: International basic safety standards. IAEA safety standards series GSR Part 3. Vienna, Austria: International Atomic Energy Agency. http://www-pub.iaea.org/books/IAEABooks/8930/Radiation-Protection-and-Safety-of-Radiation-Sources-International-Basic-Safety-Standards. December 04, 2017.
*IARC. 1997. Silica, some silicates, coal dust and para-aramid fibrils. In: IARC Monograph Volume 68. Geneva: World Health Organization, International Agency for Research on Cancer.
*IARC. 2001. Some internally deposited radionuclides. In: Ionizing radiation, part 2, Volume 78. Geneva: World Health Organization, International Agency for Research on Cancer.
*IARC. 2012. Internalized alpha-particle emitting radionuclides. IARC Monographs on the evaluation of carcinogenic risks to humans. Volume 100D. Radiation. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Monographs/vol100D/mono100D-9.pdf. November 7, 2017.
*IARC. 2014. Agents reviewed by the IARC Monographs. Volumes 1–109. Lyon, France: World Health Organization, International Agency for Research on Cancer.
*Ibrahim SA, Whicker FW. 1988. Comparative uptake of U and Th by native plants at a U production site. Health Phys 54:413–419.3350662
*Ibrahim SA, Wrenn ME, Singh NP, . 1983. Thorium concentration in human tissues from two U.S. populations. Health Phys 44(Suppl 1):213–220.6862900
*ICRP. 1966. International Commission on Radiological Protection. ICRP task group on lung dynamics, depositions and retention models for internal dosimetry of the human respiratory tract. Health Phys 21:173–207.
*ICRP. 1975. International Commission on Radiological Protection. Report of the Task Group on Reference Man. ICRP Publication 23. New York: Pergamon Press.
*ICRP. 1977. Recommendations of the International Commission on Radiological Protection. ICRP Publication 26. Vol. 1. No. 3. Oxford: Pergamon Press.
*ICRP. 1979. Limits for intakes of radionuclides by workers. International Commission on Radiological Protection. ICRP Publication 30. New York: Pergamon Press, 31, 32, 37, 100–101.
*ICRP. 1984. A compilation of the major concepts and quantities in use by ICRP. International Commission on Radiological Protection. ICRP Publication 42. Oxford: Pergamon Press.
*ICRP. 1994a. Appendix A: Age-specific biokinetic models for the alkaline earth elements and lead. Age-dependent doses to members of the public from intake of radionuclides: Part 2. Ingestion dose coefficients. International Commission on Radiological Protection. ICRP publication 67. Tarrytown, NY: International Commission on Radiological Protection, 95–120.
*ICRP. 1994b. ICRP Publication 66: Human respiratory tract model for radiological protection. International Commission on Radiological Protection.
*ICRP. 1995. ICRP Publication 69: Age-dependent doses to members of the public from intake of radionuclides: Part 3. Ingestion dose coefficients. The International Commission on Radiological Protection. Smith H, editor. Tarrytown, NY: Elsevier Science, Inc.
*ICRP. 1996. ICRP Publication 71: Age-dependent doses to members of the public from intake of radionuclides: Part 3 Inhalation dose coefficients. The International Commission on Radiological Protection. Smith H, Ed. Tarrytown, NY: Elsevier Science, Inc.
*ICRP. 2001. The ICRP database of dose coefficients workers and members of the public. Version 2.01. Thorium: International Commission on Radiological Protection. Elsevier Science Ltd.
*ICRP. 2006. Description of the model. New York, NY: International Commission on Radiological Protection.
*ICRP. 2007. Publication no. 103. The 2007 recommendations of the International Commission on Radiological Protection. Ann ICRP 37(2–4):98–99. November 27, 2017.
*ICRP. 2010. Conversion coefficients for radiological protection quantities for external radiation exposures. ICRP Publication 116, Ann ICRP 40(2–5). The International Commission on Radiological Protection and The International Commission on Radiation Units and Measurements. http://www.icrp.org/publication.asp?id=icrp%20publication%20116. February 1, 2018.
*ICRP. 2012. Compendium of dose coefficients based on ICRP Publication 60. ICRP Publication 119. Ann ICRP 41 (Suppl). The International Commission on Radiological Protection. http://www.icrp.org/publication.asp?id=ICRP%20Publication%20119. February 1, 2018.
ICRU. 1980. International Commission on Radiation Units and Measurements. ICRU Report No. 33. Washington, DC.
*Inn KGW. 1987. The National Bureau of Standards freshwater lake sediment environmental-level radioactivity standard reference material. J Radioanal Nucl Chem 115:91–112.
*IRIS. 2014. Integrated Risk Information System. Washington, DC.
*IRIS. 2017. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/. September 11, 2017.
Ishihara T, Kohno S, Hayta I, . 1978. Nine year cytogenetic follow up of a patient injected with Thorotrast. Hum Genet 42:99–108.649176
Ishikawa Y, Kagaya H, Saga K. 2004. Biomagnification of 7Be, 234Th, and 228Ra in marine organisms near the northern Pacific coast of Japan. J Environ Radioact 76(1–2):103–112.15245843
Ishikawa Y, Mori T, Kato Y, . 1992. Lung cancers associated with Thorotrast exposure: High incidence of small-cell carcinoma and implications for estimation of radon risk. Int J Cancer 52(4):570–574.1328071
Ishikawa Y, Mori T, Machinami R. 1995. Lack of apparent excess of malignant mesothelioma but increased overall malignancies of peritoneal cavity in Japanese autopsies with Thorotrast injection into blood vessels. J Cancer Res Clin Oncol 121(9–10):567–570.7559738
*Isner JM, Sazama KJ, Roberts WC. 1978. Vascular complications of thorium dioxide. Am J Med 67:1069–1074.
*Iyengar GV, Kawamura H, Dang HS, . 2004. Contents of cesium, iodine, strontium, thorium, and uranium in selected human organs of adult Asian population. Health Phys 87(2):151–159.15257215
*Ito Y, Kojiro M, Nakashima T, . 1988. Pathomorphologic characteristics of 102 cases of Thorotrast-related hepatocellular carcinoma, cholangiocarcinoma, and hepatic angiosarcoma. Cancer 62:1153–1162.2457426
*Jadon A, Mathur R. 1983. Gametogenic count and histopathological effect of thorium nitrate and uranyl nitrate on mice testes. Andrologia 15:40–43.6837951
*Jaiswal DD, Singh IS, Nair S, . 2004. Comparison of observed lung retention and urinary excretion of thorium workers and members of the public in India with the values predicted by the ICRP biokinetic model. Radiat Prot Dosimetry 112(2):237–243.15292523
*James A. 1987. A reconsideration of cells at risk and other key factors in radon daughter dosimetry. In: Hopke P, ed. Radon and its decay products: Occurrence, properties and health effects. ACS Symposium Series 331. Washington, DC: American Chemical Society, 400–418.
*James A, Roy M. 1988. Dosimetric lung models. In: Gerber G, ., ed. Age-related factors in radionuclide metabolism and dosimetry. Boston, MA: Martinus Nijhoff Publishers, 95–108.
*Jeambrun M, Pourcelot L, Mercat C, . 2012. Potential sources affecting the activity concentrations of 238U, 235U, 232Th and some decay products in lettuce and wheat samples. J Environ Monit 14(11):2902–2912.23001397
*Jeanson A, Ferrand M, Funke H, . 2010. The role of transferrin in actinide(IV) uptake: Comparison with iron(III). Chemistry 16(4):1378–1387.19950335
*Jee WS, Dockum NL, Mical RS, . 1967. Distribution of thorium daughters in bone. Ann NY Acad Sci 145:660–673.5239242
*Jensen L, Regan G, Goranson S, . 1984. Ambient monitoring of airborne radioactivity near a former thorium processing plant. Health Phys 46:1021–1033.6327571
*Jiang FS, Kuroda PK. 1987. Variation of the isotopic composition of thorium in the atmosphere. Radiochim Acta 42123–28.
*Jiang FS, Lee SC, Bakhtiar SN, . 1986. Determination of thorium, uranium and plutonium isotopes in atmospheric samples. J Radioanal Nucl Chem 100:65–72.
*Johansen C. 1967. Tumors in rabbits after injections of various amounts of thorium dioxide. NY Acad Sci 145:724
*Johannson L. 1982. Oral intake of radionuclides in the population: A review of biological factors of relevance for assessment of absorbed dose at long term waste storage. FOA Report C40161-W4. DE 83-704553.
Johannsson W, Perrault G, Savoie L, . 1968. Action of various metallic chlorides on calcaemia and phosphataemia. Br J Pharamcol Chemother 33:91–97.
*Johnson JR, Lamothe ES. 1989. A review of the dietary uptake of Th. Health Phys 56:165–168.2645247
*Joshi SR. 1987. Nondestructive determination of selected uranium and thorium-series radionuclides in biological samples. Health Phys 53:417–420.3654230
*Joyet G. 1971. The thorium-series in cigarettes and lungs of smokers. Experientia 27:85–89.
*Kamboj MP, Kar AB. 1964. Antitesticular effect of metallic and rare earth salts. J Repro Fertil 7:21–28.
*Kamijo A, Okabe K, Hirose T. 1979. Thorium dioxide granuloma of the neck with resultant fatal hemorrhage. Arch Otolaryngol 105:45–47.760706
*Kamiyama R, Ishikawa Y, Hatakeyama S, . 1988. Clinicopathological study of hematological disorders after Thorotrast administration in Japan. Blut 56:153–160.3162698
Kaneko M, Kamiya Y, Hoshino M, . 1981. Identification and mapping of Thorotrast in tissue by analytical electron microscopy. Health Phys 41:677–680.7309527
*Kato H, Schull W. 1982. Studies of the mortality of A-bomb survivors. Report 7, Part 1: Cancer mortality among atomic bomb survivors, 1950-78. Radiat Res 90:395–432.7079470
*Kato I, Kido C. 1987. Increased risk of death in Thorotrast-exposed patients during the late follow-up period. Jpn J Cancer Res 78:1187–1192.2826375
*Kato Y, Mori T, Kumatori T. 1979. Thorotrast dosimetric study in Japan. Environ Res 18:32–36.499141
*Kato Y, Mori T, Kumatori T. 1983. Estimated absorbed dose in tissues and radiation effects in Japanese Thorotrast patients. Health Phys 44(Suppl 1):273–279.6862905
*Kathren RL, Hill RL. 1992. Distribution and dosimetry of Thorotrast in USUR case 1001. Health Phys 63(1):72–88.1522012
Katzin LI. 1983. Thorium and thorium compounds. In: Grayson M, Eckroth D, eds. Kirk-Othmer encyclopedia of chemical technology, Vol 22, 3rd ed. New York, NY: John Wiley and Sons, 989–1002.
*Kaul A, Heyder J. 1972. Clearance of thorium-232 and daughters from the blood. In: Symposium: Assessment Radioactive Contam Man, 469–481.
*Kaul A, Muth H. 1978. Thorotrast kinetics and radiation dose. Results from studies in Thorotrast patients and from animal experiments. Radiat Environ Biophys 15:241–259.746119
*Kaul A, Noffz W. 1978. Tissue dose in Thorotrast patients. Health Phys 35:113–121.721479
Kaul A, Foll U, Haase VA, . 1979. Microdistribution of Thorotrast and dose to cellular structures. Environ Res 18:13–22.499131
*Kauzlaric D, Barmeir E, Luscieti P, . 1987. Renal carcinoma after retrograde pyelography with Thorotrast. Am J Radiol 148:897–898.
*Keane AT, Brewster DR. 1983. Calibration of a decay-product collection and counting apparatus for the determination of exhaled thoron. Health Phys 45:801–805.6309704
*Keane AT, Lucas HF, Markun F, . 1986. The estimation and potential radiobiological significance of the intake of radium-228 by early radium dial workers in Illinois. Health Phys 51:313–328.3744831
*Keller G, Folkerts KH. 1984. Radon-222 concentrations and decay-product equilibrium in dwellings and in the open air. Health Phys 47:385–398.6094394
*Kemmer W. 1979. A field study in 156 Thorotrast cases: Results of biophysical measurements and clinical examinations. Environ Res 18:147–151.499133
*Kemmer W, Muth H, Tranekjer F. 1971. Dose dependence of the chromosome aberration rate in Thorotrast patients. Biophysik 7:342–351.5110153
*Kemmer W, Muth H, Trandkjer F, . 1973. Chromosome aberrations caused by Thorotrast. In: 3rd International Meeting: Toxicity of Thorotrast, April 25-27, 1973. RISO Report 294:104–113.
*Kemmer W, Steinstraesser A, Muth H. 1979. Chromosome aberrations as a biological dosimeter in Thorotrast patients: Dosimetric problems. Environ Res 18:178–183.499135
*Kido C, Sasaki F, Hirota Y, . 1999. Cancer mortality of Thorotrast patients in Japan: The second series updated 1998. Radiat Res 152(6 Suppl):S81–S83.10564942
*Kobashi A, Tominaga T. 1985. Radium-228-thorium-228 dating of plant samples. Int J Appl Radiat Isot 36:547–554.
*Kojiro M, Nakashima T, Ito Y, . 1985. Thorium dioxide-related angiosarcoma of the liver. Pathomorphologic study of 29 autopsy cases. Arch Pathol Lab Med 109:853–857.3927870
*Korte N, Kollenbach M, Donivan S. 1983. The determination of uranium, thorium, yttrium, zirconium and hafnium in zircon. Analyt Chim Acta 146:267–270.
*Kotrappa P, Bhanti DP, Menon VB, . 1976. Assessment of airborne hazards in the thorium processing industry. Am Ind Hyg Assoc J 37:613–616.998494
Krey P, Fiseene I, Perry P, . n.d. Natural radioactivity in the biosphere. Environmental Measurements Laboratory, New York, NY.
*Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
*Kumar A, Ali M, Mishra P, . 2009. Thorium-induced neurobehavioural and neurochemical alterations in Swiss mice. Int J Radiat Biol 85(4):338–347.19399679
*Kumar A, Ali M, Pandey BN, . 2010. Role of membrane sialic acid and glycophorin protein in thorium induced aggregation and hemolysis of human erythrocytes. Biochimie 92(7):869–879. 10.1016/j.biochi.2010.03.008.20362640
*Kumar A, Sharma P, Ali M, . 2012. Decorporation and therapeutic efficacy of liposomal-DTPA against thorium-induced toxicity in the Wistar rat. Int J Radiat Biol 88(3):223–229.22035501
*Kuppers G. 2001. Determination of 232Th by neutron activation analysis using isotope-related ki factors. Radiat Prot Dosim 97(2):123–125.
Kurlyandskaya EB. 1970. Certain aspects of the toxicology of insoluble compounds of thorium-232 and uranium-238. In: Letavet AA, Kurlyandskaya EB, eds. The toxicology of radioactive substances, Vol. 4. New York: Pergamon Press, 1–8.
*Kuroda PK, Barbod T, Bakhtiar SN. 1987. Effect of the eruptions of Mount St. Helens and El Chichon on the ratios of thorium and uranium isotopes in rain. J Radioanal Nucl Chem 111:137–146.
*Kyle RH, Oler A, Lasser EC, . 1963. Meningioma induced by thorium dioxide. New Engl J Med 368:80–82.
*Kyoizumi S, Umeki S, Akiyama M, . 1992. Frequency of mutant T lymphocytes defective in the expression of the T-cell antigen receptor gene among radiation-exposed people. Mutat Res 265(2):173–180.1370716
*LaFlamme BD, Murray JW. 1987. Solid/solution interaction: The effect of carbonate alkalinity on adsorbed thorium. Geochim Cosmochim Acta 51:243–250.
*Lambert JPF, Wilshire FW. 1979. Neutron activation analysis for simultaneous determination of trace elements in ambient air collected on glass-fiber filters. Anal Chem 51:1346–1350.
*Laul JC, Smith MR, Thomas CW, . 1987. Analysis of natural radionuclides from uranium and thorium series in briney groundwaters. J Radioanal Nucl Chem 110:101–112.
*Lauria DC, Godoy JM. 1988. A sequential analytical method for the determination of uranium-238, thorium-232, thorium-230, thorium-228, radium228, and radium-226 in environmental samples. Sci Total Environ 70:83–99.
*Lazo EN, Roessler GS, Berven BA. 1991. Determination of uranium and thorium concentrations in unprocessed soil samples. Health Phys 61(2):231–243.1856084
*Le Du A, Sabatie-Gogova A, Morgenstern A, . 2012. Is DTPA a good competing chelating agent for Th(IV) in human serum and suitable in targeted alpha therapy? J Inorg Biochem 109:82–89.22388013
*Lenka P, Sahoo SK, Mohapatra S, . 2013. Ingestion dose from 238U, 232Th, 226Ra, 40K and 137Cs in cereals, pulses and drinking water to adult population in a high background radiation area, Odisha, India. Radiat Prot Dosimetry 153(3):328–333.22802517
*Levowitz BS, Hughes RE, Alford TC. 1963. Treatment of thorium dioxide granulomas of the neck. New Engl J Med 268:340–342.13930218
*Levy DW, Rindsberg S, Friedman AC, . 1986. Thorotrast-induced hepatosplenic neoplasia: CT identification. Am J Radiol 146:997–1004.
*Li GY, Hu N, Ding DX, . 2011. Screening of plant species for phytoremediation of uranium, thorium, barium, nickel, strontium and lead contaminated soils from a uranium mill tailings repository in South China. Bull Environ Contam Toxicol 86(6):646–652.21523506
*Li WB, Karpas Z, Salonen L, . 2009. A compartmental model of uranium in human hair for protracted ingestion of natural uranium in drinking water. Health Phys 96(6):636–645.19430216
*Li WB, Wahl W, Oeh U, . 2007. Biokinetic modelling of natural thorium in humans by ingestion. Radiat Prot Dosimetry 125(1–4):500–505.17337738
*Likhachev YuP. 1976. Pathological anatomy, etiology and pathogenesis of remote sequelae of radiation dust exposure. Arkh Patol 38:18–26. [Russian]
*Likhachev YuP, Lyarskii PP, Elovskaya LT. 1973a. Morphological changes in the lungs with chronic inhalation of thorium dioxide. Med Radiol 18:35–41. [Russian]
*Likhachev YuP, Lyarskii PP, Elovskaya LT. 1973b. Pulmonary neoplasms in rats in chronic inhalation of thorium dioxide. Vopr Onkol 19:47–54.
*Linsalata P, Franca EP, Eisenbud M. 1985. Determination of the human intake of thorium and the light rare earth elements from high and typical natural radiation environments. Trace Subst Environ Health 19:257–263.
Linsalata P, Eisenbud M, Franca EP. 1986. Ingestion estimates of thorium and the light rare earth elements based on measurements of human feces. Health Phys 50:163–167.3943969
*Linsalata P, Morse RS, Ford H, . 1989. An assessment of soil-to-plant concentration ratios for some natural analogues of the transuranic elements. Health Phys 56:33–46.2909501
*Linsalata P, Penna Franca E, Sachett I, . 1987. Radium, thorium, and the light rare earth elements in soils and vegetables grown in an area of high natural radioactivity. DOE Symp Ser 59:131–146.
*Lipchik EO, Russell SB, Raphael MJ, . 1972. Effect of Thorotrast on the canine heart. Br J Radiol 45:142–145.5058143
*Little TT, Miller G, Guilmette R. 2003. Internal dosimetry of uranium isotopes using Bayesian inference methods. Radiat Prot Dosimetry 105(1–4):413–416.14526999
*Little TT, Miller G, Guilmette R, . 2007. Uranium dose assessment: A Bayesian approach to the problem of dietary background. Radiat Prot Dosimetry 127(1–4):333–338.17623684
*Littlefield LG, Travis LB, Sayer AM, . 1997. Cumulative genetic damage in hematopoietic stem cells in a patient with a 40-year exposure to alpha particles emitted by thorium dioxide. Radiat Res 148(2):135–144.9254732
*Liu Z, Lee TS, Kotek TJ. 1992. Mortality among workers in a thorium-processing plant--a second follow-up. Scand J Work Environ Health 18(3):162–168.1615290
*Livingston HD, Cochran JK. 1987. Determination of transuranic and thorium isotopes in ocean water in solution and in filterable particles. J Radioanal Nucl Chem 115:299–308.
*Lloyd RD, Jones CW, Mays CW, . 1984. Thorium-228 retention and dosimetry in beagles. Radiat Res 98:614–628.6427842
*Lloyd RD, Angus W, Taylor GN, . 1995. Soft tissue tumors among beagles injected with 90Sr, 228Ra, or 228Th. Health Phys 69(2):272–277.7622376
*Lloyd RD, Wrenn ME, Taylor GN, . 1985. Toxicity of 228Ra and 228Th relative to 226Ra for bone sarcoma induction in beagles. Strahlentherapie [Sonderb] 80:65–69.
*Lucas HF Jr., Edgington DN, Markun F. 1970. Natural thorium in human bone. Health Phys 19:739–742.5513690
Lucas HF Jr, Markun F, May H, . 1972. Thorium daughters in the spleen of a Thorotrast case. Health Phys 23:575–576.4634939
*Ludwig T, Schwass D, Seitz G, . 1999. Intakes of thorium while using thoriated tungsten electrodes for TIG welding. Health Phys 77(4):462–469.10492354
*Luetzelschwab JW, Googins SW. 1984. Radioactivity released from burning gas lantern mantles. Health Phys 46:873–881.6706595
*Lung RJ, Harding RL, Herceg SJ, . 1978. Long-term survival with Thorotrast cervical granuloma. J Surg Oncol 10:171–177.642515
*Luz A, Linzner U, Müller WA, . 1979. Osteosarcoma induction by simultaneous incorporation of 227Th and 227Ac. Biological implications of radionuclides released from nuclear industries, Vol. 1. Vienna: International Atomic Energy Agency, 141–151.
*Luz A, Müller WA, Schaffer E, . 1985. The sensitivity of female NMRI mice of different ages for osteosarcoma induction with 227Thorium. Strahlentherapie [Sonderb] 80:178–182.
*Lytle DA, Sorg T, Wang L, . 2014. The accumulation of radioactive contaminants in drinking water distribution systems. Water Res 50:396–407.24275108
*Maletskos DJ, Keane AT, Telles NC, . 1969. Retention and absorption of Ra-224 and Th-234 and some dosimetric considerations of Ra-224 in human beings. In: May C, ed. Delayed effects of bone-seeking radionuclides. Salt Lake City, UT: University of Utah Press, 29–49.
*Martling U, Mattsson A, Travis LB, . 1999. Mortality after long-term exposure to radioactive Thorotrast: A forty-year follow-up survey in Sweden. Radiat Res 151(3):293–299.10073667
*Mausner LF. 1982. Inhalation exposures at a thorium refinery. Health Phys 42:231–236.7068387
*May CC, Young L, Worsfold PJ, . 2012. The effect of EDTA on the groundwater transport of thorium through sand. Water Res 46(15):4870–4882.22796006
*Mays CW. 1978. Endosteal dose to Thorotrast patients. Health Phys 35:123–125.721480
*Mays CW. 1988. Alpha-particle-induced cancer in humans. Health Phys 55:637–655.2844697
*Mays CW, Dougherty TF. 1972. Progress in the beagle studies at the University of Utah. Health Phys 22:793–801.5084013
*Mays CW, Lloyd RD, Taylor GN, . 1987. Cancer incidence and lifespan vs. alpha-particle dose in beagles. Health Phys 52:617–624.3570798
*Mayya YS, Prasad SK, Nambiar PPVJ, . 1986. Measurement of 220Rn in exhaled breath of Th plant workers. Health Phys 51:737–744.3781850
*McClinton LT, Schubert J. 1948. The toxicity of some zirconium and thorium salts in rats. J Pharmacol Exp Ther 94:1–6.18885606
*McElearney N, Irvine D. 1993. A study of thorium exposure during tungsten inert gas welding in an airline engineering population. J Occup Med 35(7):707–711.8396174
McInroy JF. n.d. Measurements of plutonium and metals in man. Los Alamos, NM: Los Alamos National Laboratory.
*McInroy JF, Gonzales ER, Miglio JJ. 1992. Measurement of thorium isotopes and 228Ra in soft tissues and bones of a deceased Thorotrast patient. Health Phys 63(1):54–71.1522011
*McKee PM, Snodgrass WJ, Hart DR, . 1987. Sedimentation rates and sediment core profiles of uranium-238 and thorium-232 decay chain radionuclides in a lake affected by uranium mining and milling. Can J Fish Aquat Sci 44:390–398.
*McNabb GJ, Kirk JA, Thompson JL. 1979. Radio nuclides from phosphate ore processing plants: The environmental impact after 30 years of operation. Health Phys 34:585–587.
*McNeill KG, Molla MA, Harrison JE. 1973. Distribution of thorium series nuclides in beagles after intraspinal Thorotrast injection. Health Phys 24:403–409.4698182
Mettler F. 1985. Medical effects of ionizing radiation. New York, NY: Grune and Stratton.
*Metzger R, McKlveen JW, Jenkins R, . 1980. Specific activity of uranium and thorium in marketable rock phosphate as a function of particle size. Health Phys 39:69–76.6252121
*Michael TH, Murray C. 1970. The effects of a blockading agent on the primary immune response. J Immunol 105:411–415.4914938
*Miekeley N, Kuchler IL. 1987. Interactions between thorium and humic compounds in surface waters. Inorg Chim Acta 140:315–319.
*Milic, NB, Suranji TM. 1982. Hydrolysis of the thorium(IV) ion in sodium nitrate medium. Can J Chem 60:1298–1303.
*Moffett D, Tellier M. 1978. Radiological investigations of an abandoned uranium tailings area. J Environ Qual 7:310–314.
*Mola M, Nieto A, Penalver A, . 2014. Uranium and thorium sequential separation from norm samples by using a SIA system. J Environ Radioact 127:82–87.24172603
*Molla MAR. 1975. Radionuclides in the autopsy samples from Thorotrast patients. Health Phys 28:295–297.1112728
Molla MAR, Harrison JE, McNeill KG. 1976. Doses to the cauda equina due to Thorotrast myelography. Health Phys 31:109–114.972041
Monath TP, Borden EC. 1971. Effects of Thorotrast on humoral antibody viral multiplication and interferon during infection with St. Louis encephalitis virus in mice. J Infect Dis 123:297–300.5111885
*Moore JW, Sutherland DJ. 1981. Distribution of heavy metals and radionuclides in sediments, water, and fish in an area of Great Bear Lake contaminated with mine wastes. Arch Environ Contam Toxicol 10:329–338.7259301
*Moores SR, Black A, Lambert BE, . 1980. Deposition of thorium and plutonium oxides in the respiratory tract of the mouse. DOE Symp Ser 53:103–118.
*Mori T, Kato Y. 1991. Epidemiological, pathological and dosimetric status of Japanese Thorotrast patients. J Radiat Res 32 (Suppl) 2:34–45.1823365
*Mori T, Fukutomi K, Kato Y, . 1999a. 1998 results of the first series of follow-up studies on Japanese Thorotrast patients and their relationships to an autopsy series. Radiat Res 152(6 Suppl):S72–S80.10564941
*Mori T, Kato Y, Aoki N, . 1983b. Statistical analysis of Japanese Thorotrast-administered autopsy cases--1980. Health Phys 44(Suppl 1):281–292.6575000
*Mori T, Kato Y, Kumatori T, . 1983a. Epidemiological follow-up study of Japanese Thorotrast cases--1980. Health Phys 44(Suppl 1):261.–272.6862904
*Mori T, Kato Y, Shimamini T, . 1979. Statistical analysis of Japanese Thorotrast-administered autopsy cases. Environ Res 18:231.227670
*Mori T, Kido C, Fukutomi K, . 1999b. Summary of entire Japanese Thorotrast follow-up study: Updated 1998. Radiat Res 152(6 Suppl):S84–S87.10564943
*Morton LS, Evans CV, Estes GO. 2002. Natural uranium and thorium distributions in podzolized soils and native blueberry. J Environ Qual 31(1):155–162.11837419
Müller WA. 1971. Studies on short-lived internal emitters in mice and rats. Int J Radiat Bio 20:233–243.
*Müller WA, Gijssner W, Hug O, . 1978. Late effects after incorporation of the short-lived alpha-emitters radium-224 and thorium-227 in mice. Health Phys 35:33–55.102611
*Müller WA, Luz A, Schaffer EH, . 1983. The role of time-factor and RBE for the induction of osteosarcomas by incorporated short-lived boneseekers. Health Phys 44(Suppl 1):203–212.6574999
*Müller WA, Nenot JC, Daburon ML, . 1975. Metabolic and dosimeter studies after inhalation of Th-227 in rats with regard to the risk of lung and bone tumors. Radiat Environ Biophys 11:309–318.806929
*Munita CS, Mazzilli BP. 1986. Determination of trace elements in Brazilian cigarette tobacco by neutron activation analysis. J Radioanal Nucl Chem 108:217–228.
*Mustonen R, Jantunen M. 1985. Radioactivity of size fractionated fly-ash emissions from a peat- and oil-fired power plant. Health Phys 49:1251–1260.4077527
*Nakaoka A, Fukushima M, Takagi S. 1984. Environmental effects of natural radionuclides from coal-fired power plants. Health Phys 47:407–416.6500942
*NAS/NRC. 1989. Biologic markers in reproducible toxicology. Washington, DC: National Academy of Sciences/National Research Council. National Academy Press, 15–35.
*NCRP 1971. Basic radiation protection criteria. National Council on Radiation Protection and Measurements. NCRP Report No. 39. Washington, DC.
*NCRP. 1985. A handbook of radioactivity measurements procedures. 2nd ed. Bethesda, MD: National Council on Radiation Protection and Measurements. NCRP Report No. 58.
*NCRP. 1997. Deposition, retention and dosimetry of inhaled radioactive substances. NCRP Report No. 125. Bethesda, MD: National Council on Radiation Protection and Measurements.
*Neton JW, Ibrahim SA. 1978. Alpha emitting radio nuclides in cigarette tobacco. Health Phys 35:922.
*Newton D, Rundo J, Eakins JD. 1981. Long-term retention of thorium-228 following accidental intake. Health Phys 40:291–298.7228677
Nielsen M, Albrechtsen R, Johnson NJ, . 1979. Carcinoma of the parotid gland following sialography with Thorotrast. Acta Otolaryngol 88:462–467.532622
*NIH. 2018. PubChem Open Chemistry Database. National Institutes of Health. U.S. National Library of Medicine. National Center for Biotechnology Information. https://pubchem.ncbi.nlm.nih.gov/compound/44150929#section=Top. March 7, 2018.
*NIOSH. 2014. NIOSH pocket guide to chemical hazards. Atlanta, GA.
*NIOSH. 2016. NIOSH pocket guide to chemical hazards. Index of Chemical Abstracts Service Registry Numbers (CAS No.). Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/npg/npgdcas.html. September 11, 2017.
*Nishioka H. 1975. Mutagenic activities of metal compounds in bacteria. Mutat Res 31:185–190.805366
*NNDC. 2018. Interactive chart of nuclides. National Nuclear Data Center. http://www.nndc.bnl.gov/chart/. March 5, 2018.
*NRC. 1988. Maximum permissible concentrations for uranium and thorium. Nuclear Regulatory Commission. 10 CFR 20 151:4115 and 151:4117.
*NRC. 2017a. Appendix B - Annual limits on intake (ALIs) and derived air concentrations (DACs) of radionuclides for occupational exposure. Code of Federal Regulations. Occupational Safety and Health Standards. 10 CFR 20, App B. https://www.govinfo.gov/content/pkg/CFR-2012-title10-vol1/pdf/CFR-2012-title10-vol1-part20-appB.pdf. November 27, 2017.
*NRC. 2017b. Subpart C - Occupational dose limits. Code of Federal Regulations. Nuclear Regulatory Commission. 10 CFR 20.1201-1208. https://www.gpo.gov/fdsys/pkg/CFR-2017-title10-vol1/pdf/CFR-2017-title10-vol1-part20-subpartC.pdf. November 28, 2017.
*NRC. 2017c. Subpart D - Radiation dose limits for individual members of the public. Code of Federal Regulations. Nuclear Regulatory Commission. 10 CFR 20.1301-1302. https://www.gpo.gov/fdsys/pkg/CFR-2017-title10-vol1/pdf/CFR-2017-title10-vol1-part20-subpartD.pdf. November 28, 2017.
*NTP. 2011. Ionizing radiation: Thorium dioxide. Report on carcinogens: Carcinogen profiles. National Toxicology Program. U.S. Department of Health and Human Services, Public Health Service, 243–246.
*NTP. 2016. Ionizing radiation. Report on carcinogens, Fourteenth edition. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/ionizingradiation.pdf. November 7, 2017.
*Nyberg U, Nilsson B, Travis LB, . 2002. Cancer incidence among Swedish patients exposed to radioactive Thorotrast: A forty-year follow-up survey. Radiat Res 157(4):419–425.11893244
*Oakes TW, Shank KE, Easterly CE, . 1977. Concentrations of radionuclides and selected stable elements in fruits and vegetables. Trace Subst Environ Health 11:123–132.
*Odegaard A, Ophus EM, Larsen AM. 1978. Identification of thorium dioxide in human liver cells by electron microscopic x-ray microanalysis. J Clin Pathol 31:893–896.213451
*Ogawa K, Washiyama K. 2012. Bone target radiotracers for palliative therapy of bone metastases. Curr Med Chem 19(20):3290–3300.22664247
*Okubo A, Obata H, Magara M, . 2013. Rapid collection of iron hydroxide for determination of Th isotopes in seawater. Anal Chim Acta 804:120–125.24267072
*Oliveira MS, Duarte IM, Paiva AV, . 2014. The role of chemical interactions between thorium, cerium, and lanthanum in lymphocyte toxicity. Arch Environ Occup Health 69(1):40–45.23930795
*Ondov JM, Zoller WH, Olmez I, . 1975. Elemental concentrations in the National Bureau of Standards’ environmental coal and fly ash standard reference materials. Anal Chem 47:1102–1109.
*OSHA. 2014. Limits for air contaminants. 29 CFR 1910.1000, Subpart Z, Table Z-1. Washington, DC: Occupational Safety and Health Administration.
*OSHA. 2016a. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Code of Federal Regulations. Occupational Safety and Health Standards. 29 CFR 1926.55. https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol8/pdf/CFR-2016-title29-vol8-sec1926-55.pdf. March 6, 2017.
*OSHA. 2016b. Subpart Z - Toxic and hazardous substances. Air contaminants. Code of Federal Regulations. Occupational Safety and Health Standards. 29 CFR 1910.1000. https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol6/pdf/CFR-2016-title29-vol6-sec1910-1000.pdf. March 6, 2017.
*OSHA. 2017. Subpart Z - Toxic and hazardous substances. Air contaminants. Code of Federal Regulations. Occupational Safety and Health Standards. 29 CFR 1915.1000. https://www.gpo.gov/fdsys/pkg/CFR-2017-title29-vol7/pdf/CFR-2017-title29-vol7-sec1915-1000.pdf. September 7, 2017.
*Otake M, Schull W. 1984. Mental retardation in children exposed in utero to the atomic bombs: A reassessment. Technical Report RERF TR 1-83, Radiation Effects Research Foundation, Japan.
*Parr RM, Lucas HF Jr., Griem ML. 1968. Metabolism of 232Th decay series radionuclides in man and other animals following intravascular administration of Thorotrast. ANL-7615. U.S. AEC Argonne National Lab, 97115.
*Parreira F, De Moura MC. 1979. Morphological study of the bone marrow in patients injected with thorium oxide. Environ Res 18:61–64.499145
*Patrick SJ, Cross EM. 1948. Some effects of the administration of thorium nitrate to mice. Can J Res 26:303–316.
*Pavlovskaia NA. 1973. Basic patterns of the metabolism of Th232 and its decay products in the body. Gig Sanit 11:55–58. [Russian]
*Pavlovskaia NA, Makeeva LG, Orlianskaia RL. 1969. Distribution of thorium in rat bones with various routes of administration and different chemical compounds of thorium. Gig Sanit 34:27–31.
*Pavlovskaia NA, Makeeva LG, Zel’tser MR. 1974a. Excretion of radionuclides of the thorium-232 (thorium-228, radium-224, lead-212) series from a rat’s body during the uptake of thorium compounds in respiratory organs. Gig Sanit 9:42–45. [Russian]
*Pavlovskaia NA, Provotorov AV, Makeeva LG. 1974b. Behavior of thorium-228 and its daughter isotopes in the body of rats when administered perorally. Gig Tr Prof Zabol 5:36–39. [Russian]
*Percival DR, Martin DB. 1974. Sequential determination of radium-226, radium-228, actinium-227, and thorium isotopes in environmental and process waste samples. Anal Chem 46:1742–1749.4415732
*Perkins RW, Kalkwarf DR. 1956. Determination of thorium in urine. Anal Chem 28:1989–1993.
Perry DL, Tsao L. n.d. Thorium species on basalt surfaces. Berkeley, CA: Lawrence Berkeley Laboratory.
*Peter E, Lehmann M. 1981. Interaction of thorium with blood serum proteins in vivo. Int J Radiat Biol Relat Stud Phys Chem 40:445–450.
*Peter-Witt E, Volf V. 1984. Efficacy of different diethylenetriaminepentaacetic acid treatment schedules for removal of thorium-234 from simulated wounds in rats. Int J Radiat Biol Relat Stud Phys Chem Med 45:45–50.6607231
*Peter-Witt E, Wolf V. 1985. Comparison of diethylenetriaminepentaacetic acid calcium chelate and diethylenetriaminepentaacetic acid zinc chelate in removing thorium-234 from the rat. Health Phys 49:395–404.4030331
Peter-Witt E, Volf V. 1985. The distribution and decorporation of 234Th in the rat as influenced by the mass of thorium administered. Strahlentherapie [Sonderb] 80:183–185.
*Petrow HG, Strehlow CD. 1967. Spectrophotometric determination of thorium in bone ash using arsenazo. 3. Anal Chem 39:265–267.6040697
*Picer M, Strohal P. 1968. Determination of thorium and uranium in biological materials. Anal Chim Acta 40:131–136.5634425
*Pillai KC, Matkar VM. 1987. Determination of plutonium and americium in environmental samples and assessment of thorium in bone samples from normal and high background areas. J Radioanal Nucl Chem 115:217–229.
Planas-Bohne F, Taylor DM, Lamble G, . 1982. The localization of metallic radionuclides in abscesses in rats. Br J Radiol 55:289–293.7066640
*Platford RF, Joshi SR. 1986. The chemistry of uranium and related radionuclides in Lake Ontario (USA, Canada) waters. J Radioanal Nucl Chem 106:333–344.
*Platford RF, Joshi SR. 1988. Dose rates to aquatic life near a uranium waste site. Health Phys 54:63–68.3335442
Pleskach SD. 1985. Determination of U and Th in urine by neutron activation. Health Phys 48:303–307.3980216
*Platz EA, Wiencke JK, Kelsey KT, . 2000. Chromosomal aberrations and hprt mutant frequencies in long-term American Thorotrast survivors. Int J Radiat Biol 76(7):955–961.10923619
*Polednak AP, Stehney AF, Lucas HF. 1983. Mortality among male workers at a thorium-processing plant. Health Phys 44(Suppl 1):239–251.6305876
*Popper H, Thomas LB, Telles NC. 1978. Development of hepatic angiosarcoma in man induced by vinyl chloride, Thorotrast, and arsenic. Comparison with cases of unknown etiology. Am J Pathol 92:349–376.567014
*Poston TM. 1982. The bio accumulation potential of thorium and uranium in rainbow trout Salmo-nairdneri. Bull Environ Contam Toxicol 28:682–690.7104502
*Powell BA, Hughes LD, Soreefan AM, . 2007. Elevated concentrations of primordial radionuclides in sediments from the Reedy River and surrounding creeks in Simpsonville, South Carolina. J Environ Radioact 94(3):121–128.17350148
*Premuzic ET, Francis AJ, Lin M, . 1985. Induced formation of chelating agents by Pseudomonas aeruginosa grown in presence of thorium and uranium. Arch Environ Contam Toxicol 14:759–768.3935054
*Priest ND, Humphreys JA, Kathren RL, . 1992. The distribution of Thorotrast in human bone marrow: A case report. Health Phys 63(1):46–53.1522010
*Pulhani VA, Dafauti S, Hegde AG, . 2005. Uptake and distribution of natural radioactivity in wheat plants from soil. J Environ Radioact 79(3):331–46.15607519
*Rae BK, Brodell GK, Haaga JR, . 1986. Visceral CT findings associated with Thorotrast. J Comput Assist Tomogr 10:57–61.3944318
*Rangarajan C, Eapen CD, Gopalakrishnan SS. 1986. Measured values of the dry deposition velocities of atmospheric aerosols carrying natural and fallout radionuclides using artificial collectors. Water Air Soil Pollut 27:305–314.
*Raymond DP, Dufield JR, Williams DR. 1987. Complexation of plutonium and thorium in aqueous environments. Inorg Chim Acta 140:309–313.
*Rayno DR. 1989. Assimilation of thorium isotopes into terrestrial vegetation. Sci Total Environ 80(23):243–266.2762804
*Rich AL, Crosby EC. 2013. Analysis of reserve pit sludge from unconventional natural gas hydraulic fracturing and drilling operations for the presence of technologically enhanced naturally occurring radioactive material (TENORM). New Solutions 23(1):117–135.23552651
*Riedel WR, Hirschberg AK, Kaul A, . 1979. Comparative investigations on the biokinetics of colloidal thorium, zirconium, and hafnium dioxides in animals. Environ Res 28:127–139.
Riedel W, Dalheimer A, Said M, . 1983. Recent results of the German Thorotrast study dose relevant physical and biological properties of Thorotrast equivalent colloids. Health Phys 44:293–298.6862906
*Roeck DR, Reavey TC, Hardin JM. 1987. Partitioning of natural radionuclides in the waste streams of coal-fired utilities. Health Phys 52:311–324.3818296
*Roper AR, Stabin MG, Delapp RC, . 2013. Analysis of naturally-occurring radionuclides in coal combustion fly ash, gypsum, and scrubber residue samples. Health Phys 104(3):264–269.23361421
*Roth P, Hollriegl V, Li WB, . 2005. Validating an important aspect of the new ICRP biokinetic model of thorium. Health Phys 88(3):223–228.15706142
*RTECS. 1989. Registry of Toxic Effects of Chemical Substances. February 14, 1989.
*Rubin P, Casarett G. 1968. Clinical radiation pathology. Philadelphia, PA: W.B. Sanders Company, 33.
*Ruhmann AG, Berliner DL. 1965. Serum lactic dehydrogenase levels in adult beagle dogs with internally deposited radionuclides. Radiat Res 26:287–294.5833762
*Sadamori N, Miyajima J, Okajima S, . 1987. Japanese patients with leukaemia following the use of Thorotrast including a patient with marked chromosomal rearrangements. Acta Haematol 77:11–14.3107315
*Saisho H, Tanaka M, Nakamura K, . 1988. Determination of traces of uranium and thorium in microelectronics constituent materials. J Res Natl Bureau Stand 93:398–400.
*Saito H, Hisanaga N, Okada Y, . 2003. Thorium-232 exposure during tungsten inert gas arc welding and electrode sharpening. Ind Health 41(3):273–278.12916759
*Salaymeh S, Kuroda PK. 1987. Variation of the thorium to uranium ratio in rain: Thorium-230 chronology of the eruptions of Mt. St. Helens and El Chichon volcanoes. J Radioanal Nucl Chem 116:261–269.
*Saldanha MJ, Shah VR, Nambiar PPUJ. 1975. Health Assessment of thorium nitrate plant workers of Indian rare earths. Indian J Ind Med 21:114–123.
*SANSS. 1989. Structure and Nomenclature Search System. February 14, 1989.
*Santschi PH. 1984. Particle flux and trace metal residence time in natural waters. Limnol Oceanogr 29:1100–1108.
*Santschi PH, Li YH, Adler DM, . 1983. The relative mobility of natural (thorium, lead and polonium) and fallout (plutonium, americium, cesium) radionuclides in the coastal marine environment: Results from model ecosystems (MERL) and Narragansett Bay. Geochim Cosmochim Acta 47:201–210.
*Sasaki F, Kido C, Sobue T, . 1999. Cancer mortality in Thorotrast-exposed patients in Japan: Aichi series. Int J Clin Oncol 4(2):69–73.
*Sasaki MS, Takatsuji T, Ejima Y, . 1987. Chromosome aberration frequency and radiation dose to lymphocytes by alpha-particles from internal deposit of Thorotrast. Radiat Environ Biophys 26:227–238.3659273
*Schery SD. 1985. Measurements of airborne lead-212 and radon-220 at varied indoor locations within the United States. Health Phys 49:1061–1067.4077512
*Schlemmer HP, Liebermann D, Naser V, . 2000. Locoregional late effects of paravascular Thorotrast deposits: Results of the German Thorotrast study. J Neuroradiol 27(4):253–263.11223617
*Schmied SA, Brunnermeier MJ, Schupfner R, . 2012. Dating ivory by determination of 14C, 90Sr and 228/232Th. Forensic Sci Int 221(1–3):5–10.22717552
*Scott JK, Neuman WF, Bonner JF. 1952. The distribution and excretion of thorium sulphate. J Pharmacol Exp Therapeut 106:286–290.
Serio CS, Henninb CB, Toohey RE, . 1983. Measurement of lymphoblastogenic activity from thorium workers. Int J Radiat Biol 44:251–256.
Sheppard MI. 1980. The environmental behavior of uranium and thorium. Atomic Energy Canada Ltd., AECL-6795.
*Shiga J, Maruyama T, Takahashi H, . 1993. Effect of PSK, a protein-bound polysaccharide preparation, on liver tumors of Syrian hamsters induced by Thorotrast injection. Acta Pathol Jpn 43(9):475–480.8237367
*Shtangeeva I. 2010. Uptake of uranium and thorium by native and cultivated plants. J Environ Radioact 101(6):458–463.18649976
*Shtangeeva I, Ayrault S, Jain J. 2005. Thorium uptake by wheat at different stages of plant growth. J Environ Radioact 81(2–3):283–293.15795040
*Sill CW. 1977. Simultaneous determination of U-238, U-234, Th-230, Ra226, and PB.210 in uranium ores, dusts, and mill tailings. Health Phys 33:393–404.591316
*Sill CW, Willis CP. 1962. Fluorometric determination of submicrogram quantities of thorium. Anal Chem 34:954–964.
*Simpson HJ, Trier RM, Li YH, . 1984. Field experiment determinations of distribution coefficients of actinide elements in alkaline lake environments. Nucl Waste Geochem, 326–342.
*Simpson HJ, Trier RM, Toggweiler JR, . 1982. Radionuclides in Mono Lake, California, USA. Science 216:512–514.17735739
Sindelar WF, Costa J, Ketcham AS. 1978. Osteosarcoma associated with Thorotrast administration: Report of two cases and literature review. Cancer 42:2604–2609.365315
*Singh NP, Wrenn ME. 1988. Determinations of actinides in biological and environmental samples. Sci Total Environ 70:187–203.2834820
*Singh NP, Bennett D, Saccomanno G, . 1985. Concentrations of lead-210 in uranium miners’ lungs and its states of equilibria with uranium-238 uranium-234 and thorium-230. Occup Radiat Saf Min 2:503–506.
*Singh NP, Bennett DB, Wrenn ME, . 1986. Concentrations of 210Pb and its states of equilibrium with 238U 234U and 230Th in U miners’ lungs. Health Phys 51:501–507.3759463
*Singh NP, Bennett DD, Wrenn ME, . 1987. Concentrations of alpha-emitting isotopes of uranium and thorium in uranium miners’ and millers’ tissues. Health Phys 53:261–266.3623915
*Singh, NP, Ibrahim SA, Cohen N, . 1979. Simultaneous determination of alpha-emitting radionuclides of thorium plutonium in human tissues including bone. Analytical Chem 51:1978–1981.
*Singh NP, Lewis LL, Wrenn ME. 1985. Uranium thorium and plutonium in bones from the general population of the United States. Comm Eur Communities Issue 9250:231–241.
*Singh NP, Wrenn ME, Archer VE, . 1981. Uranium-238, uranium-234 and thorium-230 in uranium miners’ lungs. Radiation Hazards in Mining, Control Measurements, Medical Aspects, International Conference 236–239.
Singh NP, Wrenn ME, Ibrahim SA, . 1982. Thorium concentration in human tissues from two geographic locations of the United States. In: National radiation environment. New York, NY: John Wiley and Sons, 258–268.
*Singh NP, Wrenn ME, Ibrahim SA. 1983. Plutonium concentration in human tissues: Comparison to thorium. Health Phys 44:469–476.
*Singh NP, Wrenn ME, McInroy JF, . 1986. Ratios of 234U, 238U and 230Th in dog lungs exposed to U ore dust: An interlaboratory comparison. Health Phys 50:292–297.3949522
*Singh NP, Zimmerman CJ, Taylor GN, . 1988. The beagle: An appropriate experimental animal for extrapolating the organ distribution pattern of Th in humans. Health Phys 54:293–299.3346160
*Sollman T, Brown ED. 1907. Pharmacologic investigations on thorium. Am J Physiol 18:426–456.
*Soudek P, Kufner D, Petrova S, . 2013. Composition of hydroponic medium affects thorium uptake by tobacco plants. Chemosphere 92(9):1090–1098.23466096
*Spiers FW, Beddow AH. 1983. Sites of incidence of osteosarcoma in the long bones of man and beagle. Health Phys 44(Suppl 1):49–64.6575001
*Spiethoff A, Wesch H, Wegener K, . 1992. The effects of Thorotrast and quartz on the induction of lung tumors in rats. Health Phys 63(1):101–110.1325960
*Stannard JN. 1988. Radioactivity and health: A history. DOE/RL/01830T59.
Stanley RB Jr. 1983. Thorium-dioxide induced pharyngeal hemorrhage. Am J Otolaryngol 4:437–441.6660378
*Stanley RB Jr, Calcaterra TC. 1981. Management of cervical thorium dioxide granulomas. Arch Otolaryngol 107:631–634.7283829
*Stehney AF. 1999. Organ distribution of thorium in thorium workers: Good agreement with new models of the International Commission on Radiological Protection. Radiat Res 152(6 Suppl):S110–S114.10564949
*Stehney AF, Lucas HF. 2000. Thorium isotopes in autopsy samples from thorium workers. Health Phys 78(1):8–14.
*Stehney AF, Polednak AP, Rundo J, . 1980. Health status and body radioactivity of former thorium workers. Argonne, IL, Argonne National Laboratory 80–37:44.
*Steinstrasser A. 1981. Biophysical investigations of the dose-effect relationship in chromosome aberrations of human lymphocytes caused by Thorotrast deposits. Radiat Env Biophys 19:1–15.7220794
*Stevens W, Nabors CJ Jr, Berliner DL. 1967. A comparison of serum transaminase levels and other serum constituents in dogs burdened with 239Pu, 228-Th, 228-RA and 226-Ra. NY Acad Sci 145:817–829.
*Stougaard M, Praestholm J, Stoier M. 1984. Late effects of perivascular injection of Thorotrast in the neck. J Laryngol Otol 98:1003–1007.6491478
*Stover BJ. 1981. Toxicology of thorium-228 in young adult beagles: Potential relationship to the thorium fuel cycle. In: Wrenn ME, ed. Actinides in man and animals: Proc Snowbird Actinide Workshop. Salt Lake City, UT: University of Utah, 483–500.
Stover BJ. 1983. Effects of Thorotrast in humans. Health Phys 44:253–257.6190776
Stover BJ, Atherton DR, Buster DS, . 1965a. The Th-228 decay series in adult beagles: Ra-224 PB-212 and Bi-212 in selected bones and soft tissues. Radiat Res 26:132–145.5825702
Stover BJ, Atherton DR, Buster DS, . 1965b. The Th-228 decay series in adult beagles: Ra224 Pb212 and Bi-212 in blood and excreta. Radiat Res 26:226–243.5833758
*Stover BJ, Atherton DR, Keller, . 1960. Metabolism of Th-228 decay series in adult beagle dogs. Radiation Res 12:657–671.13835023
*Stradling N, Phipps A, Hodgson A. 2001. Dosimetric models for thorium and practical problems in assessing intakes. Radiat Prot Dosimetry 97(2):89–94.11843366
*Sullivan MF. 1980a. Absorption of actinide elements from the gastrointestinal tract of rats, guinea pigs and dogs. Health Phys 38:159–171.6246038
*Sullivan MF. 1980b. Absorption of actinide elements from the gastrointestinal tract of neonatal animals. Health Phys 38:173–185.6246039
*Sullivan MF, Miller BM, Ryan JL. 1983. Absorption of thorium and protactinium from the gastrointestinal tract in adult mice and rats and neonatal rats. Health Phys 44:425–428.6841106
*Summers DE, Chung EB. 1986. Thorotrast associated anemia and bone marrow hypoplasia. J Nat1 Med Assoc 78:1161–1165.
*Sunta CM, Dang HS, Jaiswal DD. 1987. Thorium in man and environment: Uptake and clearance. J Radional Nucl Chem 115:149–158.
*Sussman S, Terbrugge KG, Solt LC, . 1980. Thorotrast induced meningioma case report. J Neurosurg 52:834–837.7381542
*Syao-Shan Y. 1970a. The behavior of thorium dioxide in rats after intratracheal and intraperitoneal administration. In: Letavet AA, Kurlyandskaya EB, eds. The toxicology of radioactive substances, Vol. 4. New York, NY: Pergamon Press, 30–41.
*Syao-Shan Y. 1970b. Comparative toxicity of soluble and insoluble compounds of thorium-232. In: Letavet AA, Kurlyandskaya EB, eds. The toxicology of radioactive substances, Vol. 4. New York, NY: Pergamon Press, 9–19.
Syao-Shan Y. 1970c. The effect of thorium dioxide on the peripheral blood of rats. In: Letavet AA, Kurlyandskaya EB, eds. The toxicology of radioactive substances, Vol. 4. New York, NY: Pergamon Press, 42–57.
*Syao-Shan, Y. 1970d. The effect of thorium dioxide on arterial pressure and threshold of stimulation of the nerve muscle apparatus in rats. In: Letavet AA, Kurlyandskaya EB, eds. The toxicology of radioactive substances, Vol. 4. New York, NY: Pergamon Press, 58–65.
*Tadmor J. 1986. Atmospheric release of volatilized species of radioelements from coal fired plants. Health Phys 50:270–273.3949518
*Tandon SK, Dikshith TSS, Behari JR, . 1975. Effect of thorium nitrate in male albino rats. Ind Health 13:221–225.
*Tanosaki S, Minamihisamatsu M, Ishihara T, . 1999. Chromosome aberrations in bone marrow cells from Japanese patients with thorotrastosis. Radiat Res 152(6 Suppl):S128–S132.10564953
*Taskayev AI, Popova ON, Alexakhin RM, . 1986. Root absorption of radon-222 and its transfer into above ground plant organs. Health Phys 50:589–594.3700110
*Taylor DM, Chipperfield AR, James AC. 1971. Effects of tetracycline on the deposition of plutonium and related elements in rat bone. Health Phys 21:197–204.5094190
*Taylor GN, Jee WSS, Christensen WR, . 1966. Thorium-228 induced fractures in beagles. Health Phys 12:889–893.5956204
*Taylor GN, Mays CW, Lloyd RD, . 1986. Liver cancer induction by 241Am and Thorotrast in deer mice and grasshopper mice. Strahlen Therapie 80(Suppl):172–177.
*Teixeira-Pinto AA, Azevedo e Silva MC. 1979. Chromosome radiation induced aberrations in patients injected with thorium dioxide. Environ Res 18:225–230.499139
*Telles MC, Thomas LB, Popper H, . 1979. Evolution of Thorotrast induced hepatic angiosarcomas. Environ Res 18:74–87.574081
*Terry KW, Hewson GS. 1995. Thorium lung burdens of mineral sands workers. Health Phys 69(2):233–242.7622370
*Terry KW, Hewson GS, Meunier G. 1995. Thorium excretion in feces by mineral sands workers. Health Phys 68(1):105–109.7661919
*Thomas RG. 1957. The metabolism of thorium-230 administered by intratracheal injection to the rat. Rochester, NY: University of Rochester, Atomic Energy Project Report UR-480, 1–26.
Thomas RG. 1968. Transport of relatively insoluble materials from lung to lymph nodes. Health Phys 14:111–117.
*Thomas RG, Lie R, Scott JK. 1963. Thorium distribution and excretion studies. I. Patterns following parenteral administration. Health Phys 9:153–163.13981111
*Thurman GB, Mays CW, Taylor GN, . 1971. Growth dynamics of beagle osteosarcomas. Growth 35:119–125.5291157
*Toohey RE, Bertelli L, Sugarman SL, . 2011. Dose coefficients for intakes of radionuclides via contaminated wounds. Health Phys 100(5):508–514.21451321
*Torstenfelt B. 1986. Migration of the actinides, thorium, protactinium, uranium, neptunium, plutonium and americium in clay. Radiochem Acta 39:105112.
*Traikovich M. 1970. Absorption, distribution and excretion of certain soluble compounds of natural thorium. In: Letavet AA, Kurlyandskaya EB, eds. The toxicology of radioactive substances, Vol. 4. New York, NY: Pergamon Press, 20–29.
*Travis LB, Hauptmann M, Gaul LK, . 2003. Site-specific cancer incidence and mortality after cerebral angiography with radioactive Thorotrast. Radiat Res 160(6):691–706.14640794
*Travis LB, Land CE, Andersson M, . 2001. Mortality after cerebral angiography with or without radioactive Thorotrast: An international cohort of 3,143 two-year survivors. Radiat Res 156(2):136–150.11448234
*TRI16. 2017. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. September 11, 2017.
*Twitty BL, Boback MW. 1970. Rapid determination of thorium in urine by thermal neutron activation analysis. Anal Chim Acta 49:19–24.5410885
*Umeki S, Kyoizumi S, Kusunoki Y, . 1991. Flow cytometric measurements of somatic cell mutations in Thorotrast patients. Jpn J Cancer Res 82(12):1349–1353.1778756
*UNSCEAR. 1977. Sources and effects of ionizing radiation. United Nations Scientific Committee on the Effects of Atomic Radiation. United Nations Publication E.77.IX.l. New York, NY: United Nations, 95–96.
*UNSCEAR. 1982. Ionizing radiation: Sources and biological effects. United Nations Scientific Committee on the Effects of Atomic Radiation. New York, NY: United Nations.
*UNSCEAR. 1986. Genetic and somatic effects of ionizing radiation. United Nations Scientific Committee on the Effects of Atomic Radiation. New York, NY: United Nations.
*UNSCEAR. 1988. Sources, effects and risks of ionization radiation. United Nations Scientific Committee on the Effects of Atomic Radiation. New York, NY: United Nations.
*Van Kaick G, Dalheimer A, Hornik S, . 1999. The German Thorotrast study: Recent results and assessment of risks. Radiat Res 152(6 Suppl):S64–S71.10564940
*Van Kaick G, Lieberman D, Lorenz D, . 1983. Recent results on the German Thorotrast study-epidemiological results and dose effect relationships in Thorotrast patients. Health Phys 44:299–306.6862907
Van Kaick G, Wesch H, Luhrs H, . 1986. Radiation induced primary liver tumors in Thorotrast patients. Recent Results Cancer Res 100:16–22.3738160
*van Kaick G, Wesch H, Luhrs H, . 1991. Neoplastic diseases induced by chronic alpha-irradiation-epidemiological, biophysical and clinical results of the German Thorotrast Study. J Radiat Res 32 Suppl 2:20–33.
*Vandenborre J, Grambow B, Abdelouas A. 2010. Discrepancies in thorium oxide solubility values: Study of attachment/detachment processes at the solid/solution interface. Inorg Chem 49(19):8736–8748.20804204
*Velten RJ, Jacobs BJ. 1982. Determination of thorium in drinking water, Method 910. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory.
*VIEW Database. 1989. Agency for Toxic Substances and Disease Registry (ATSDR), Office of External Affairs, Exposure and Disease Registry Branch, Atlanta, GA. June 20, 1989.
*Visfeldt J, Andersson M. 1995. Pathoanatomical aspects of malignant haematological disorders among Danish patients exposed to thorium dioxide. APMIS 103(1):29–36.7695889
*Visfeldt J, Poulsen H. 1972. On the histopathology of liver and liver tumors in thorium dioxide patients. Acta Path Micro Scand Sect A:97–108.
*Vocaturo G, Colombo F, Zanoni M, . 1983. Human exposure to heavy metals: Rare earth pneumoconiosis in occupational workers. Chest 83:780–783.6839821
*Waligorski MPR, Jasinska M, Schwabenthan J. 1985. Enhanced nuclear radiation from camera lenses. Health Phys 49:491–494.4030337
*Wargotz ES, Sidawy MK, Jannotta FS. 1988. Thorotrast associated gliosarcoma including comments on Thorotrast use and review of sequelae with particular reference to lesions of the central nervous system. Cancer 62:58–60.3289727
*Weast RC, ed. 1983. CRC handbook of chemistry and physics. 64th ed. Boca Raton, FL: CRC Press, Inc., B149–B150.
*Web_elements. 2014a. Thorium compounds: Thorium tetrachloride. The University of Sheffield and Web Elements Ltd., UK [May 29, 2014]. http://www.webelements.com/compounds/thorium/thorium_tetrachloride.html.
*Web_elements. 2014b. Thorium compounds: Thorium sulphate nonahydrate. The University of Sheffield and Web Elements Ltd., UK [May 29, 2014]. http://www.webelements.com/compounds/thorium/Th-1_SO4-2_OH2_9.html.
*Wegener K, Wesch H. 1979. Pathological changes of lymph nodes in Thorotrast patients: Pathoanatomical autoradiographical and quantitative investigations. Environ Res 18:245–255.387404
Wegener K, Hasenohrl K, Wesch H. 1983. Recent results of the German Thorotrast study pathoanatomical changes in animal experiments and comparison to human thorotrastosis. Health Phys 44(Suppl 1):307–316.6862908
*Wegener K, Wesch H, Kampmann H. 1976. Investigations into human thorotrastosis tissue concentrations of thorium-232 and late effects in 13 autopsy cases. Virchows Arch Path Anat Histol 371:131–143.
*Weissman SH, Carpenter RL, Newton GJ. 1983. Respirable aerosols from fluidized bed coal combustion: Element composition of fly ash. Environ Sci Tech 17:65–71.
*Welford GA, Sutton DC, Morse RS, . 1958. Determination of thorium in urine. Am Ind Hyg Assoc J 19:464–468.13617208
*Wesch H, van Kaick G, Riedel W, . 1983. Recent results of the German Thorotrast study statistical evaluation of animal experiments with regard to the nonradiation effects in human thorotrastosis. Health Phys 44:317–321.
*West CM. 1962. An evaluation of the health physics problems from thorium and its daughters in a thorium purification and fabrication process. Health Phys 8:279–297.14006292
*Westin J, Lanner LO, Weinfeld A, . 1973. Renal pelvic carcinoma after Thorotrast pyelography: Case report. Acta Med Scand 194:141–143.
*Wong SH. 1988. Effects of some metallic compounds on Klebsiella. Bull Environ Contam Toxicol 40:525–531.3285918
*WHO. 2005. WHO air quality guidelines for particulate matter, ozone, nitrogen dioxide and sulfur dioxide. 2nd ed. Geneva, Switzerland: World Health Organization.
*WHO. 2010. WHO guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
*WHO. 2011. Guidelines for drinking-water quality, fourth edition. Geneva, Switzerland: World Health Organization.
*WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
*Woodliff HJ, Cohen G, Gallon W. 1972. Chromosome aberrations in lymphocytes from patients exposed to thorium dioxide. Med J Australia 2:768–771.4674809
*Wrenn ME, Singh NP, Cohen N, . 1981. Thorium in human tissues. NTIS NUREG/CR-1227, 1–97.
*Wrenn ME, Singh NP, Paschoa AS, . 1985. Concentrations of uranium and thorium isotopes in uranium millers’ and miners’ tissues. NTIS NUREG/CR-4382/GAR, 1–47.
*Wrenn ME, Singh NP, Saccomanno G. 1983. Uranium and thorium isotopes and their state of equilibria in lungs from uranium miners. Health Phys 44:385–389.6862915
*Wrenn ME, Taylor GN, Stevens W, . 1986. DOE life-span radiation effects studies in experimental animals at University of Utah, Division of Radiobiology. In: Life-span radiation effects in animals: What can they tell us? Conference: U.S. Department of Energy, 830951.
*Wustrow TP, Behbehani AA, Wiebecks B. 1988. Thorotrast-induced oro- and hypopharyngeal fibrosis with recurrent bleeding. J Cranio-Maxillo-Facial Surg 16:315–319.
*Yamada S, Hosoda S, Tateno H, . 1983. Survey of Thorotrast associated liver cancers in Japan. J Natl Cancer Inst 70:31–35.6296518
*Yamamoto Y, Chikawa J, Uegaki Y, . 2010. Histological type of Thorotrast-induced liver tumors associated with the translocation of deposited radionuclides. Cancer Sci 101(2):336–340.19917057
*Yamamoto Y, Usuda N, Takatsuji T, . 2009. Long incubation period for the induction of cancer by Thorotrast is attributed to the uneven irradiation of liver cells at the microscopic level. Radiat Res 171(4):494–503.19397450
*Yang HS, Nozaki Y, Sakai H, . 1986. Natural and man-made radionuclide distributions in Northwest Pacific deep sea sediments: Rates of sedimentation, bioturbation and radium-226 migration. Geochem J 20:29–40.
*Yantasee W, Sangvanich T, Creim JA, . 2010. Functional sorbents for selective capture of plutonium, americium, uranium, and thorium in blood. Health Phys 99(3):413–419.20699706
*Young WN, Tebrock HA. 1958. The treatment of exposure to thorium and uranium with a chelating agent and supportive measures. Ind Med Surg (Annual Meeting) 27:229–232.
*Zoller WH, Gladney ES, Duce RA. 1974. Atmospheric concentrations and sources of trace metals at the South Pole. Science 183:198–200.17777264