# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Sam Keith, M.S., C.H.P.
- ATSDR, Division of Toxicology and Human Health Sciences, Atlanta, GA

- David W. Wohlers, Ph.D.
- Lisa Ingerman, Ph.D., DABT
- SRC, Inc., North Syracuse, NY

## REVIEWERS

- Interagency Minimal Risk Level Workgroup:
  Includes ATSDR; National Center for Environmental Health (NCEH); National Institute of Occupational Health and Safety (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).
- Additional reviews for science and/or policy:
  ATSDR, Division of Community Health Investigations; ATSDR, Office of Science; NCEH, Division of Laboratory Science; NCEH, Division of Environmental Health Science and Practice.