# VERSION HISTORY

Date | Description
September 2019 | Update of data in Chapters 2, 3, and 7
October 2014 | Addendum to the toxicological profile
October 1990 | Final toxicological profile released