# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding thorium in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on MRLs and the rationale for not deriving MRLs for thorium.

Table 7-1 Regulations and Guidelines Applicable to Thorium

Agency | Description | | Information | | Reference
Air
EPA | RfC | | No data | | IRIS 2017
WHO | Air quality guidelines | | No data | | WHO 2010
NRC | Dose limits for individual members of the public | | | | NRC 2017c
NRC | Radiation | | | | NRC 2017c
NRC | Total effective dose equivalent | | 0.1 rem (1 mSv) in a year | | NRC 2017c
IAEA | Recommended dose limits for the public | | | | IAEA 2014
IAEA | Radiation | | | | IAEA 2014
IAEA | Effective dose | | 1 mSv in a year | | IAEA 2014
IAEA | Lens of the eye equivalent dose | | 15 mSv in a year | | IAEA 2014
IAEA | Skin equivalent dose | | 50 mSv in a year | | IAEA 2014
IAEA | Hands and feet equivalent dose | | No data | | IAEA 2014
Water & Food
EPA | Drinking water standards and health advisories | | | | EPA 2012
EPA | Gross alpha particle activity | | | | EPA 2012
EPA | 10^−4^ Cancer risk | | 15 pCi/L | | EPA 2012
EPA | National primary drinking water regulations | | | | EPA 2009
EPA | Alpha and beta/photon emitters | | | | EPA 2009
EPA | Alpha emitters | | | | EPA 2009
EPA | MCL | | 15 pCi/L | | EPA 2009
EPA | Public health goal | | zero | | EPA 2009
EPA | Beta/gamma emitters | | | | EPA 2009
EPA | MCL | | 4 mrem/year | | EPA 2009
EPA | RfD | | No data | | IRIS 2017
WHO | Drinking water quality guidelines | | | | WHO 2017
WHO | ^228^Th, ^230^Th, or ^232^Th | | 1 Bq/L | | WHO 2017
FDA | EAFUS | | No data^a^ | | FDA 2013
FDA | Allowable level in bottled water | | | | FDA 2017
FDA | Gross alpha particle activity | | 15 pCi/L | | FDA 2017
Cancer
HHS | Carcinogenicity classification | | | | NTP 2016
HHS | Thorium dioxide | | Known to be a human carcinogen | | NTP 2016
EPA | Carcinogenicity classification | | No data | | IRIS 2017
IARC | Carcinogenicity classification | | | | IARC 2012
IARC | ^232^Th (as Thorotrast) | | Group 1^b^ | | IARC 2012
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards and construction | | No data | | OSHA 2016a, 2016b, 2017
NIOSH | REL (up to 10-hour TWA) | | No data | | NIOSH 2016
NRC | Lung clearance class^c^ | | | | NRC 2017a
NRC | Thorium oxides and hydroxides | | Y | | NRC 2017a
NRC | All other thorium compounds | | W | | NRC 2017a
NRC | Occupational ALIs and DACs for inhalation | | | | NRC 2017a
NRC | [underlined: Isotope] | [underlined: Class] ^c^ | [underlined: ALI (µCi)] ^d^ | [underlined: DAC (µCi/mL)] | NRC 2017a
NRC | ^226^Th | W | 2×10^2^ | 6×10^−8^ | NRC 2017a
NRC | ^226^Th | Y | 1×10^+2^ | 6×10^−8^ | NRC 2017a
NRC | ^227^Th | W | 3×10^−1^ | 1×10^−10^ | NRC 2017a
NRC | ^227^Th | Y | 3×10^−1^ | 1×10^−10^ | NRC 2017a
NRC | ^228^Th | W | 1×10^+2^ bone surface (2×10^−2^) | 4×10^−12^ | NRC 2017a
NRC | ^228^Th | Y | 2×10^−2^ | 7×10^−12^ | NRC 2017a
NRC | ^229^Th | W | 9×10^−4^ bone surface (2×10^−3^) | 4×10^−13^ | NRC 2017a
NRC | ^229^Th | Y | 2×10^−3^ bone surface (3×10^−3^) | 1×10^−12^ | NRC 2017a
NRC | ^230^Th | W | 6×10^−3^ bone surface (2×10^−2^) | 3×10^−12^ | NRC 2017a
NRC | ^230^Th | Y | 2×10^−2^ bone surface (2×10^−2^) | 6×10^−12^ | NRC 2017a
NRC | ^231^Th | W | 6×10^3^ | 3×10^−6^ | NRC 2017a
NRC | ^231^Th | Y | 6×10^3^ | 3×10^−6^ | NRC 2017a
NRC | ^232^Th | W | 1×10^−3^ bone surface (3×10^−3^) | 5×10^−13^ | NRC 2017a
NRC | ^232^Th | Y | 3×10^−3^ bone surface (4×10^−3^) | 1×10^−12^ | NRC 2017a
NRC | ^234^Th | W | 2×10^2^ | 8×10^−8^ | NRC 2017a
NRC | ^234^Th | Y | 2×10^2^ | 6×10^−8^ | NRC 2017a
NRC | Occupational ALIs for ingestion | | | | NRC 2017a
NRC | [underlined: Isotope] | | [underlined: ALI (µCi)] ^d^ | | NRC 2017a
NRC | ^226^Th | | 5×10^3^ stomach wall (5×10^3^) | | NRC 2017a
NRC | ^227^Th | | 1×10^2^ | | NRC 2017a
NRC | ^228Th^ | | 6×10^0^ bone surface (1×10^1^) | | NRC 2017a
NRC | ^229^Th | | 6×10^−1^ bone surface (1×10^0^) | | NRC 2017a
NRC | ^230^Th | | 4×10^0^ bone surface (9×10^0^) | | NRC 2017a
NRC | ^231^Th | | 4×10^3^ | | NRC 2017a
NRC | ^232^Th | | 7×10^−1^ bone surface (2 ×10^0^) | | NRC 2017a
NRC | ^234^Th | | 3×10^2^ lower large intestine wall (4×10^2^) | | NRC 2017a
NRC | Quantity of radioactive material requiring licensing | | | | NRC 2017a
NRC | [underlined: Isotope] | | [underlined: Activity (Ci)] | | NRC 2017a
NRC | ^226^Th | | [underlined: 10] | | NRC 2017a
NRC | ^227^Th | | [underlined: 0.01] | | NRC 2017a
NRC | ^228^Th | | [underlined: 0.001] | | NRC 2017a
NRC | ^229^Th | | [underlined: 0.001] | | NRC 2017a
NRC | ^230^Th | | [underlined: 0.001] | | NRC 2017a
NRC | ^23`^Th | | [underlined: 100] | | NRC 2017a
NRC | ^232^Th | | [underlined: 100] | | NRC 2017a
NRC | ^234^Th | | [underlined: 10] | | NRC 2017a
NRC | Thorium (natural) | | [underlined: 100] | | NRC 2017a
NRC | Occupational dose limits | | | | NRC 2017b
NRC | Radiation | | | | NRC 2017b
NRC | Adults | | | | NRC 2017b
NRC | Annual limit, the more limiting of: | | | | NRC 2017b
NRC | Total effective dose equivalent | | 5 rem (0.05 Sv) in a year | | NRC 2017b
NRC | -or- | | | | NRC 2017b
NRC | Sum of the deep-dose equivalent and the committed dose equivalent to any individual organ or tissue other than the lens of the eye | | 50 rem (0.5 Sv) in a year | | NRC 2017b
NRC | Lens of the eye dose equivalent | | 15 rem (0.15 Sv) in a year | | NRC 2017b
NRC | Shallow-dose equivalent to the skin of the whole body or to the skin of any extremity | | 50 rem (0.5 Sv) in a year | | NRC 2017b
NRC | Minors | | 10% of the annual dose limits specified for adult workers | | NRC 2017b
NRC | Embryo/fetus, dose equivalent during entire pregnancy for a declared pregnant woman | | 0.5 rem (5 mSv) | | NRC 2017b
IAEA | Recommended occupational dose limits | | | | IAEA 2014
IAEA | Radiation | | | | IAEA 2014
IAEA | Effective dose | | 20 mSv per year, averaged over | | IAEA 2014
IAEA | | | 5 consecutive years, and not to exceed | | IAEA 2014
IAEA | | | 50 mSv in any single year | | IAEA 2014
IAEA | Lens of the eye equivalent dose | | 20 mSv per year, averaged over | | IAEA 2014
IAEA | | | 5 consecutive years, and not to exceed | | IAEA 2014
IAEA | | | 50 mSv in any single year | | IAEA 2014
IAEA | Skin equivalent dose | | 500 mSv in a year | | IAEA 2014
IAEA | Hands and feet equivalent dose | | 500 mSv in a year | | IAEA 2014
IAEA | Recommended public dose limits | | | | IAEA 2014
IAEA | Radiation | | | | IAEA 2014
IAEA | Effective dose | | 1 mSv in a year | | IAEA 2014
IAEA | Lens of the eye equivalent dose | | 15 mSv in a year | | IAEA 2014
IAEA | Skin equivalent dose | | 50 mSv in a year | | IAEA 2014
Emergency Criteria
EPA | AEGLs-air | | No data | | EPA 2016
DOE | Protective Action Criteria (PACs)-air | | | | DOE 2016b
DOE | Thorium | | | | DOE 2016b
DOE | PAC-1^e^ | | 30 mg/m^3^ | | DOE 2016b
DOE | PAC-2^e^ | | 330 mg/m^3^ | | DOE 2016b
DOE | PAC-3^e^ | | 2,000 mg/m^3^ | | DOE 2016b
DOE | Thorium hydroxide | | | | DOE 2016b
DOE | PAC-1^e^ | | 30 mg/m^3^ | | DOE 2016b
DOE | PAC-2^e^ | | 330 mg/m^3^ | | DOE 2016b
DOE | PAC-3^e^ | | 2,000 mg/m^3^ | | DOE 2016b
DOE | Thorium dioxide | | | | DOE 2016b
DOE | PAC-1^e^ | | 30 mg/m^3^ | | DOE 2016b
DOE | PAC-2^e^ | | 330 mg/m^3^ | | DOE 2016b
DOE | PAC-3^e^ | | 2,000 mg/m^3^ | | DOE 2016b
DOE | Thorium(IV) nitrate | | | | DOE 2016b
DOE | PAC-1^e^ | | 2.9 mg/m^3^ | | DOE 2016b
DOE | PAC-2^e^ | | 32 mg/m^3^ | | DOE 2016b
DOE | PAC-3^e^ | | 190 mg/m^3^ | | DOE 2016b
DOE | Thorium nitrite | | | | DOE 2016b
DOE | PAC-1^e^ | | 30 mg/m^3^ | | DOE 2016b
DOE | PAC-2^e^ | | 330 mg/m^3^ | | DOE 2016b
DOE | PAC-3^e^ | | 2,000 mg/m^3^ | | DOE 2016b
DOE | Thorium oxalate | | | | DOE 2016b
DOE | PAC-1^e^ | | 30 mg/m^3^ | | DOE 2016b
DOE | PAC-2^e^ | | 330 mg/m^3^ | | DOE 2016b
DOE | PAC-3^e^ | | 2,000 mg/m^3^ | | DOE 2016b

a The EAFUS list of substances contains ingredients added directly to food that FDA has either approved as food additives or listed or affirmed as GRAS.

b Group 1: carcinogenic to humans

c Class refers to the retention (approximately days, weeks, or years) in the pulmonary region of the lung. This classification applies to a range of clearance half-times of <10 days for D, 10–100 days for W, and >100 days for Y.

d When an ALI is defined by the stochastic dose limit, this value alone is given. When an ALI is determined by the non-stochastic dose limit to an organ, the organ or tissue to which the limit applies is shown, and the ALI for the stochastic limit is shown in parentheses.

e Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2016a).

- PAC-1 values are based on the applicable AEGL-1, ERPG-1, or TEEL-1 values
- PAC-2 values are based on the applicable AEGL-2, ERPG-2, or TEEL-2 values
- PAC-3 values are based on the applicable AEGL-3, ERPG-3, or TEEL-3 values

AEGL = acute exposure guideline levels; ALI = annual limit on intake; DAC = derived air concentration; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IAEA = International Atomic Energy Agency; IARC = International Agency for Research on Cancer; IRIS = Integrated Risk Information System; MCL = maximum contaminant level; NIOSH = National Institute for Occupational Safety and Health; NRC = Nuclear Regulatory Commission; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = Protective Action Criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit values; TWA = time-weighted average; WHO = World Health Organization