# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Data pertaining to the chemical identity (that is, the common terms or symbols used for the identification of the element) of thorium are listed in Table 4-1.

Table 4-1 Chemical Identity of Thorium and Compounds^a^

Characteristic | Thorium | Thorium dioxide | Thorium nitrate (tetrahydrate) | Thorium fluoride (tetrahydrate)
Synonym(s)^b^ and registered trade name(s) | ^232^Th, thorium metal, pyrophoric | Thoria, Thorotrast | No data | Thorium tetrafluoride
Chemical formula | Th | ThO_2_ | Th(NO_3_)_4_ ● 4H_2_O | ThF_4_ ● 4H
Chemical structure^c^ | Th^d^ | O=Th=O | [image] | [image]
CAS Registry Number | 7440-29-1^c^ | 1314-20-1^c^ | 13470-07-0 | 13709-59-6

Characteristic | Thorium dicarbonate | Thorium chloride^e^ | Thorium sulfate^e^
Synonym(s)^b^ and registered trade name(s) | Thorium carbonate^f^ | Thorium tetrachloride; thorium(IV) chloride; thorium chloride; tetrachlorothorium | Thorium disulphate; sulfuric acid, thorium; thorium sulfate nonahydrate; thorium sulfate 9water; thorium (IV) sulfate 9-water
Chemical formula | Th(CO_3_)_2_ | ThCl_4_ | Th(SO_4_)_2_·9H_2_O
Chemical structure^c^ | O_3_C=Th=CO_3_
CAS Registry Number | 19024-62-5 | 10026-08-1, 54327-76-3 | 10381-37-0

a All information obtained from HSDB 1990, except where noted.

b Structures are based on tetra valency of thorium unless otherwise stated.

c CAS 1990.

d SANSS 1988.

e Web_elements 2014a, 2014b.

f NIH 2018.

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

The physical and chemical properties of elemental thorium and a few representative water-soluble and insoluble thorium compounds are presented in Table 4-2. Water-soluble thorium compounds include the chloride, fluoride, nitrate, and sulfate salts (Weast 1983). These compounds dissolve fairly readily in water. Soluble thorium compounds, as a class, have greater bioavailability than the insoluble thorium compounds. Water-insoluble thorium compounds include the dioxide, dicarbonate, hydroxide, oxalate, and phosphate salts. Thorium dicarbonate is soluble in concentrated sodium carbonate (Weast 1983). Thorium metal and several of its compounds are commercially available. No general specifications for commercially prepared thorium metal or compounds have been established. Manufacturers prepare thorium products according to contractual specifications (Hedrick 1985).

Thorium is a metallic element of the actinide series. It exists in several isotopic forms. The isotope ^232^Th is a naturally occurring element that is radioactive. It decays through the emission of a series of alpha and beta particles, gamma radiation, and the formation of daughter products, finally yielding the stable isotope of lead, ^208^Pb. The decay series of ^232^Th, together with that of ^238^U and ^235^U, are shown in Figure 4-1. It can be seen from Figure 4-1 that the isotopes ^234^Th and ^230^Th are produced during the decay of naturally occurring ^238^U, the isotope ^228^Th during the decay of ^232^Th, and the isotopes ^231^Th and ^227^Th during the decay of naturally occurring ^235^U. Of these naturally produced isotopes of thorium, only ^232^Th, ^230^Th, and ^228^Th have long enough half-lives to be environmentally significant. More than 99.99% of natural thorium is ^232^Th; the rest is ^230^Th and ^228^Th.

Including artificially produced isotopes, there are 12 isotopes of thorium with atomic masses ranging from 223 to 234. All are radioactive and decay with the emission of alpha or beta particles and/or gamma radiation (Weast 1983). The percent occurrence and the energies of the major alpha and beta particles emitted by these isotopes are shown in Table 4-3. In general, the alpha particles are more intensely ionizing and less penetrating than the beta particles. The gamma radiation is the most penetrating of the three, but it has the least ionizing intensity. Alpha particles do not penetrate external skin to a sufficient depth to produce biological damage due to the protective effect of the epidermis. However, alpha particles emitted from thorium deposited in the lung are able to penetrate lung tissue and produce adverse biological damage since the protective coating of the lung tissue is very thin. In turn, beta particles are able to penetrate the skin to a sufficient depth to cause biological effects in the skin just below the epidermis. Likewise, they penetrate lung tissues to a greater depth. Gamma rays can generally pass through all tissue and interact with tissue at any depth.

Table 4-2 Physical and Chemical Properties of Thorium and Compounds

Property | Thorium (Th) | Thorium dioxide (ThO_2_) | Thorium nitrate, tetrahydrate (Th(NO_3_)_4_ ● 4H_2_O) | Thorium fluoride, tetrahydrate (ThF_4_ ● 4H)
Molecular weight | 232.04^a^ | 264.04^a^ | 552.12^a^ | 380.09^a^
Color | Gray^a^ | White^b^ | Colorless^a^ | Not known
Physical state | Solid^a^ | Powdery solid^b^ | Crystalline solid^a^ | Crystalline solid^a^
Odor | Not known | Not known | Not known | Not known
Melting point, °C | ≈1,700^b^ | 3,220±50^a^ | 500 (decomposes) | 100 (−H_2_O)^a^
Boiling point, °C | ≈4,500^b^ | 4,400^b^ | Not applicable | 140–100 (−2H_2_O)^a^
Autoignition temperature | Not applicable | Not applicable | Not applicable | Not applicable
Solubility:
Water | Insoluble^a^ | Insoluble^b^ | Very soluble^b^ | 0.017 g/100 cc H_2_O (25°C)^a^
Organic solvents | Soluble in HCl, H_2_SO_4_, slightly soluble in HNO_3_^a^ | Soluble in hot H_2_SO_4_; insoluble in dilute acid alkali^a^ | Very soluble in alcohol; slightly soluble in acetone^a^ | Insoluble in HF^a^
Density (g/cm^3^) | 11.7^a^ | 9.7^b^ | Not known | Not known
Partition coefficients | Not applicable | Not applicable | Not applicable | Not applicable
Vapor pressure at 20 °C | Not applicable | Not applicable | Not applicable | Not applicable
Henry’s law constant at 25 °C | Not applicable | Not applicable | Not applicable | Not applicable
Refractive index | Not applicable | 2.20 (liquid)^a^ | Not applicable | Not applicable
Flashpoint | Not applicable | Not applicable | Not applicable | Not applicable
Flammability limits | Not applicable | Not applicable | Not applicable | Not applicable
Conversion factors | 1 pCi=1.2 fg^c^ of ^228^Th | 1 pCi=1.2 fg^c^ of ^228^Th | 1 pCi=1.2 fg^c^ of ^228^Th | 1 pCi=1.2 fg^c^ of ^228^Th
Conversion factors | 1 pCi=9.1 µg of ^232^Th | 1 pCi=9.1 µg of ^232^Th | 1 pCi=9.1 µg of ^232^Th | 1 pCi=9.1 µg of ^232^Th
Conversion factors | 1 pCi=48 fg^c^ of ^230^Th | 1 pCi=48 fg^c^ of ^2230^Th | 1 pCi=48 fg^c^ of ^230^Th | 1 pCi=48 fg^c^ of ^230^Th

Property | Thorium carbonate Th(CO_3_)_2_ | Thorium chloride^d^ ThCl_4_ | Thorium sulfate^d^ Th(SO_4_)_2_ 9H_2_O
Molecular weight | 352.06^a^ | 373.849 | 586.303
Color | Not known | White to gray | White
Physical state | Not known | Crystalline solid | Crystalline solid
Odor | Not known | Not known | Not known
Melting point, °C | Not known | 770 | 400 (dehydrates)
Boiling point, °C | Not known | 921 | Not known
Autoignition temperature | Not applicable | Not known | Not known
Solubility:
Water | Insoluble^a^ | Soluble | 4.2 g/100 g H_2_O
Organic solvents | Soluble in HCl, H_2_SO_4_, slightly soluble in HNO_3_^a^ | Not known | Not known
Density (g/cm^3^) | Not known | 4.59 | 2.8
Partition coefficients | Not applicable | Not known | Not known
Vapor pressure at 20 °C | Not applicable | Not known | Not known
Henry’s law constant at 25 °C | Not applicable | Not known | Not known
Refractive index | Not applicable | Not known | Not known
Flashpoint | Not applicable | Not known | Not known
Flammability limits | Not applicable | Not known | Not known
Conversion factors | 1 pCi=1.2 fg^c^ of ^228^Th
Conversion factors | 1 pCi=9.1 µg of ^232^Th
Conversion factors | 1 pCi=48 fg^c^ of ^230^Th

a Weast 1983.

b Hawley 1981.

c 1 fg = 10^−9^ µg; 1 pCi = 10^−12^ Ci.

d Web_elements 2014a, 2014b.

Figure 4-1 Uranium and Thorium Isotope Decay Series Showing the Sources and Decay Products of the Two Naturally Occurring Isotopes of Thorium

Table 4-3 Percent Occurrence and the Energies of the Major Alpha Particles Emitted by Thorium Isotopes with Atomic Masses Ranging from 223 to 234

Isotope | Percentage in natural thorium | Major alpha energies^a^ MEV (abundances) | Half-life
^223^Th | 0 | 7.286 (26%); 7.298 (66%); 7.323 (13%) | 0.60 seconds
^224^Th | 0 | 7.000 (19%); 7.170 (79%) | 1.04 seconds
^225^Th | 0 | 6.441 (13.5%); 6.478 (39%); 6.501 (12.6%); 6.797 (8.1%) | 8.75 minutes
^226^Th | 0 | 6.234 (22.8%); 6.337 (75.5%) | 30.57 minutes
^227^Th | 0 | 5.757 (20.4%); 5.987 (23.5%); 6.038 (24.2%) | 18.70 days
^228^Th | Very small | 5.340 (26.0%); 5.423 (73.4%) | 1.91 years
^229^Th | 0 | 4.815 (9.3%); 4.845 (56.2%); 4.901 (10.2%) | 7.93×10^3^ years
^230^Th | Very small | 4.621 (23.4%); 4.687 (76.3%) | 7.54×10^4^ years
^231^Th | 0 | Beta-only emitter^b^; (0.392 MeV total) | 25.52 hours
^232^Th | >99.99% | 3.947 (21.7%); 4.012 (78.2%) | 1.40×10^10^ years
^233^Th | 0 | Beta-only emitter^b^; (1.243 MeV total) | 21.8 minutes
^234^Th | 0 | Beta-only emitter^b^; (0.27e MeV total) | 24.10 days

a All but a few of these isotopes also emit gamma radiation.

b The values in parentheses are the decay energies for the beta particles.

MeV = million electron volt

Source: Weast 1983; NNDC 2018

Alpha particles give up all of their energy in a very short distance and, hence, produce ionization. Beta particles produce less dense ionization, and gamma rays produce less yet. In general, the severity of biological effects of exposures to ionizing radiations is proportional to the density of the ionization produced by their passage through tissue.

Finely divided thorium metal is pyrophoric in air, and thorium ribbon burns in air to give the oxide. The metal also reacts vigorously with hydrogen, nitrogen, the halogens, and sulfur. Thorium compounds are stable in +4 oxidation state (Katzin 1983). Details of thorium chemistry are given by Katzin (1983).

When the solubility of a low-solubility thorium compound is different than expected or reported, the cause could be differences in surface form due to external factors, such as pH or concentrations of two thorium forms at grain boundaries. Vandenborre et al. (2010) scanned the surface of sintered thorium oxide using x-ray photoelectron spectroscopy (XPS) and found it to consist of two forms, 80% ThO_2_ and 20% ThO_x_(OH)_y_(H_2_O)_z_, which have different solubilities. The rate of surface detachment for this oxide was measured, then ^239^Th was added and the surface attachment rate was determined. The net balance disagreed with the thermodynamic calculation for pure ThO_2_.