# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR THORIUM

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to thorium.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen was conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, and chemical interactions for thorium. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of thorium have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of thorium are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

Health Effects; Species; Human; Laboratory mammals; Route of exposure; Inhalation; Oral; Dermal (or ocular); Parenteral (these studies will be considered supporting data); Health outcome; Death; Systemic effects; Body weight effects; Respiratory effects; Cardiovascular effects; Gastrointestinal effects; Hematological effects; Musculoskeletal effects; Hepatic effects; Renal effects; Dermal effects; Ocular effects; Endocrine effects; Immunological effects; Neurological effects; Reproductive effects; Developmental effects; Other noncancer effects; Cancer
Toxicokinetics; Absorption; Distribution; Metabolism; Excretion; PBPK models; Biomarkers; Biomarkers of exposure; Biomarkers of effect; Interactions with other chemicals

### B.1.1 Literature Search

The current literature search was intended to update the existing 1990 toxicological profile for thorium; thus, the literature search was restricted to studies published between January 1988 to June 2017. The following main databases were searched in June 2017:

- PubMed
- National Library of Medicine’s TOXLINE
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for thorium. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to thorium were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
6/2017 | ((((“Thorium/toxicity”[mh] OR “Thorium/adverse effects”[mh] OR “Thorium/poisoning”[mh] OR “Thorium/pharmacokinetics”[mh]) OR (“Thorium”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR (“Thorium”[mh] AND toxicokinetics[mh:noexp]) OR (“Thorium/blood”[mh] OR “Thorium/cerebrospinal fluid”[mh] OR “Thorium/urine”[mh]) OR (“Thorium”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Thorium”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR a“transcription, genetic “[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“Thorium/antagonists and inhibitors”[mh]) OR (“Thorium/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Thorium”[mh] AND cancer[sb]) OR (“Thorium/pharmacology”[majr])) OR ((“Thorium Compounds/toxicity”[mh] OR “Thorium Compounds/adverse effects”[mh] OR “Thorium Compounds/poisoning”[mh] OR “Thorium Compounds/pharmacokinetics”[mh]) OR (“Thorium Compounds”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR (“Thorium Compounds”[mh] AND toxicokinetics[mh:noexp]) OR (“Thorium Compounds/blood”[mh] OR “Thorium Compounds/cerebrospinal fluid”[mh] OR “Thorium Compounds/urine”[mh]) OR (“Thorium Compounds”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Thorium Compounds”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic “[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“Thorium Compounds/antagonists and inhibitors”[mh]) OR (“Thorium Compounds/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Thorium Compounds”[mh] AND cancer[sb]) OR (“Thorium Compounds/pharmacology”[majr])) OR (“thorium nitrate”[nm])) AND (1988/01/01 : 3000[dp] OR 1988/01/01 : 3000[mhda])) OR ((“Nitric acid, thorium(4+) salt, tetrahydrate”[tw] OR “Thorium nitrate tetrahydrate”[tw] OR “Thorium fluoride (ThF4), tetrahydrate, (T-4)-”[tw] OR “Thorium fluoride”[tw] OR “Thorium tetrafluoride”[tw] OR “Thorium dicarbonate”[tw] OR “Thorium carbonate”[tw]) AND (1988/01/01 : 3000[dp] OR 1988/01/01 : 3000[crdt] OR 1988/01/01 : 3000[edat])) OR ((((“Thorium”[tw] OR “232Th”[tw] OR “228Th”[tw] OR “Thoria”[tw] OR “Thorianite”[tw] OR “Thorotrast”[tw] OR “Thortrast”[tw] OR “Umbrathor”[tw]) OR (“radiothorium”[tw]) OR (“(232)th”[tw] OR “th-232”[tw] OR “th232”[tw] OR “(226)th”[tw] OR “226th”[tw] OR “th-226”[tw] OR “th226”[tw] OR “(227)th”[tw] OR “227th”[tw] OR “th-227”[tw] OR “th227”[tw] OR “(228)th”[tw] OR “th-228”[tw] OR “th228”[tw] OR “(229)th”[tw] OR “229th”[tw] OR “th-229”[tw] OR “th229”[tw] OR “(230)th”[tw] OR “230th”[tw] OR “th-230”[tw] OR “th230”[tw] OR “(231)th”[tw] OR “231th”[tw] OR “th-231”[tw] OR “th231”[tw] OR “(234)th”[tw] OR “234th”[tw] OR “th-234”[tw] OR “th234”[tw] OR “(238)th”[tw] OR “238th”[tw] OR “th-238”[tw] OR “th238”[tw] OR “(239)th”[tw] OR “239th”[tw] OR “th-239”[tw] OR “th239”[tw])) NOT medline[sb]) AND (1988/01/01 : 3000[dp] OR 1988/01/01 : 3000[crdt] OR 1988/01/01 : 3000[edat])); ((“thorium”[tw] AND (1988/01/01 : 3000[dp] OR 1988/01/01 : 3000[crdt] OR 1988/01/01 : 3000[edat])) AND (to[sh] OR po[sh] OR ae[sh] OR pk[sh] OR (me[sh] AND (“humans”[mh] OR “animals”[mh])) OR ci[sh] OR bl[sh] OR cf[sh] OR ur[sh] OR “environmental exposure”[mh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR ((“Computational biology”[mh] OR “Medical Informatics”[mh] OR Genomics[mh] OR Genome[mh] OR Proteomics[mh] OR Proteome[mh] OR Metabolomics[mh] OR Metabolome[mh] OR Genes[mh] OR “Gene expression”[mh] OR Phenotype[mh] OR genetics[mh] OR genotype[mh] OR Transcriptome[mh] OR (“Systems Biology”[mh] AND (“Environmental Exposure”[mh] OR “Epidemiological Monitoring”[mh] OR analysis[sh])) OR “Transcription, Genetic “[mh] OR “Reverse transcription”[mh] OR “Transcriptional activation”[mh] OR “Transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, Messenger”[mh] OR “RNA, Transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “Reverse Transcriptase Polymerase Chain Reaction”[mh] OR “Base Sequence”[mh] OR “Trans-activators”[mh] OR “Gene Expression Profiling”[mh])) OR cancer[sb] OR “pharmacology”[sh:noexp] OR thorium/ai OR thorium compounds/ai OR toxicokinetics[mh:noexp])) NOT (((((“Thorium/toxicity”[mh] OR “Thorium/adverse effects”[mh] OR “Thorium/poisoning”[mh] OR “Thorium/pharmacokinetics”[mh]) OR (“Thorium”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR (“Thorium”[mh] AND toxicokinetics[mh:noexp]) OR (“Thorium/blood”[mh] OR “Thorium/cerebrospinal fluid”[mh] OR “Thorium/urine”[mh]) OR (“Thorium”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Thorium”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic “[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“Thorium/antagonists and inhibitors”[mh]) OR (“Thorium/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Thorium”[mh] AND cancer[sb]) OR (“Thorium/pharmacology”[majr])) OR ((“Thorium Compounds/toxicity”[mh] OR “Thorium Compounds/adverse effects”[mh] OR “Thorium Compounds/poisoning”[mh] OR “Thorium Compounds/pharmacokinetics”[mh]) OR (“Thorium Compounds”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR (“Thorium Compounds”[mh] AND toxicokinetics[mh:noexp]) OR (“Thorium Compounds/blood”[mh] OR “Thorium Compounds/cerebrospinal fluid”[mh] OR “Thorium Compounds/urine”[mh]) OR (“Thorium Compounds”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Thorium Compounds”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic “[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“Thorium Compounds/antagonists and inhibitors”[mh]) OR (“Thorium Compounds/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Thorium Compounds”[mh] AND cancer[sb]) OR (“Thorium Compounds/pharmacology”[majr])) OR (“thorium nitrate”[nm])) AND (1988/01/01 : 3000[dp] OR 1988/01/01 : 3000[mhda])) OR ((“Nitric acid, thorium(4+) salt, tetrahydrate”[tw] OR “Thorium nitrate tetrahydrate”[tw] OR “Thorium fluoride (ThF4), tetrahydrate, (T-4)-”[tw] OR “Thorium fluoride”[tw] OR “Thorium tetrafluoride”[tw] OR “Thorium dicarbonate”[tw] OR “Thorium carbonate”[tw]) AND (1988/01/01 : 3000[dp] OR 1988/01/01 : 3000[crdt] OR 1988/01/01 : 3000[edat])) OR ((((“Thorium”[tw] OR “232Th”[tw] OR “228Th”[tw] OR “Thoria”[tw] OR “Thorianite”[tw] OR “Thorotrast”[tw] OR “Thortrast”[tw] OR “Umbrathor”[tw]) OR (“radiothorium”[tw]) OR (“(232)th”[tw] OR “th-232”[tw] OR “th232”[tw] OR “(226)th”[tw] OR “226th”[tw] OR “th-226”[tw] OR “th226”[tw] OR “(227)th”[tw] OR “227th”[tw] OR “th-227”[tw] OR “th227”[tw] OR “(228)th”[tw] OR “th-228”[tw] OR “th228”[tw] OR “(229)th”[tw] OR “229th”[tw] OR “th-229”[tw] OR “th229”[tw] OR “(230)th”[tw] OR “230th”[tw] OR “th-230”[tw] OR “th230”[tw] OR “(231)th”[tw] OR “231th”[tw] OR “th-231”[tw] OR “th231”[tw] OR “(234)th”[tw] OR “234th”[tw] OR “th-234”[tw] OR “th234”[tw] OR “(238)th”[tw] OR “238th”[tw] OR “th-238”[tw] OR “th238”[tw] OR “(239)th”[tw] OR “239th”[tw] OR “th-239”[tw] OR “th239”[tw])) NOT medline[sb]) AND (1988/01/01 : 3000[dp] OR 1988/01/01 : 3000[crdt] OR 1988/01/01 : 3000[edat])))
Toxline
6/2017 | 7440-29-1[rn] OR 1314-20-1[rn] OR 13470-07-0[rn] OR 13823-29-5[rn] OR 13453-50-4[rn] OR 13709-59-6[rn] OR 19024-62-5[rn] OR 15571-75-2[rn] OR 15623-47-9[rn] OR 14274-82-9[rn] OR 15594-54-4[rn] OR 14269-63-7[rn] OR 14932-40-2[rn] OR 15065-10-8[rn] OR 34293-72-6[rn] OR 51696-50-5[rn]; “thorium” OR “232Th” OR “228Th” OR “Thoria” OR “Thorianite” OR “Thorotrast” OR “Thortrast” OR “Umbrathor” OR “radiothorium” OR “(232)th” OR “th-232” OR “th232” OR “(226)th” OR “226th” OR “th-226” OR “th226” OR “(227)th” OR “227th” OR “th-227” OR “th227” OR “(228)th” OR “th-228” OR “th228”; “(229)th” OR “229th” OR “th-229” OR “th229” OR “(230)th” OR “230th” OR “th-230” OR “th230” OR “(231)th” OR “231th” OR “th-231” OR “th231” OR “(234)th” OR “234th” OR “th-234” OR “th234” OR “(238)th” OR “238th” OR “th-238” OR “th238” OR “(239)th” OR “239th” OR “th-239” OR “th239”
Toxcenter
6/2017 | FILE ‘TOXCENTER’ ENTERED AT 11:28:36 ON 02 JUN 2017; CHARGED TO COST=EH011.13.01.01; L3 10638 SEA FILE=TOXCENTER 7440-29-1; L4 4202 SEA FILE=TOXCENTER 1314-20-1 OR 13470-07-0 OR 13453-50-4 OR 19024-62-5 OR 15571-75-2 OR 15623-47-9 OR 14274-82-9 OR 15594-54-4 OR 14269-63-7 OR 14932-40-2 OR 15065-10-8 OR 34293-72-6 OR 51696-50-5; L5 233 SEA FILE=TOXCENTER 13823-29-5 OR 13709-59-6; L9 14008 SEA FILE=TOXCENTER L3 OR L4 OR L5; L12 14141 SEA FILE=TOXCENTER L9 NOT TSCATS/FS; L14 13439 SEA FILE=TOXCENTER L12 NOT PATENT/DT; L15 9269 SEA FILE=TOXCENTER L14 AND PY>=1988; ACT TOXQUERY/Q; ---------; L16 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L17 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L18 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L19 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L20 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L21 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L22 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L23 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L24 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?) L25 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L26 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L27 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L28 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L29 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L30 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L31 QUE (ENDOCRIN? AND DISRUPT?); L32 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L33 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L34 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?) L35 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L36 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L37 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L38 QUE (NEPHROTOX? OR HEPATOTOX?); L39 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L40 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L41 QUE L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29 OR L30 OR L31 OR L32 OR L33 OR L34 OR L35 OR L36 OR L37 OR L38 OR L39 OR L40; L42 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L43 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L44 QUE L41 OR L42 OR L43; L45 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?); L46 QUE L44 OR L45; ---------; L48 3483 SEA FILE=TOXCENTER L15 AND L46 AND L9; L51 722 SEA FILE=TOXCENTER L48 AND MEDLINE/FS; L52 439 SEA FILE=TOXCENTER L48 AND BIOSIS/FS; L53 2310 SEA FILE=TOXCENTER L48 AND CAPLUS/FS; L54 12 SEA FILE=TOXCENTER L48 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L55 3010 DUP REM L51 L52 L54 L53 (473 DUPLICATES REMOVED) ANSWERS ‘1-3010’ FROM FILE TOXCENTER; L*** DEL 722 S L48 AND MEDLINE/FS; L*** DEL 722 S L48 AND MEDLINE/FS; L56 722 SEA FILE=TOXCENTER L55; L*** DEL 439 S L48 AND BIOSIS/FS; L*** DEL 439 S L48 AND BIOSIS/FS; L57 301 SEA FILE=TOXCENTER L55; L*** DEL 2310 S L48 AND CAPLUS/FS; L*** DEL 2310 S L48 AND CAPLUS/FS; L58 1981 SEA FILE=TOXCENTER L55; L*** DEL 12 S L48 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L*** DEL 12 S L48 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L59 6 SEA FILE=TOXCENTER L55; L60 2288 SEA FILE=TOXCENTER (L56 OR L57 OR L58 OR L59) NOT MEDLINE/FS; D SCAN L60

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS ^a^
6/2017 | Compounds searched: 7440-29-1; 1314-20-1; 13470-07-0; 13823-29-5; 13453-50-4; 13709-59-6; 19024-62-5; 15571-75-2; 15623-47-9; 14274-82-9; 15594-54-4; 14269-63-7; 14932-40-2; 15065-10-8; 34293-72-6; 51696-50-5
NTP
6/2017 | Terms searched separately:; 7440-29-1; 1314-20-1; 13470-07-0; 13823-29-5; 13453-50-4; 13709-59-6; 19024-62-5; 15571-75-2; 15623-47-9; 14274-82-9; 15594-54-4; 14269-63-7; 14932-40-2; 15065-10-8; 34293-72-6; 51696-50-5; thorium; 232Th; 228Th; Thoria; Thorianite; Thorotrast; Thortrast; Umbrathor; radiothorium; (232)th; th-232; th232; (226)th; 226th; th-226; th226; (227)th; 227th; th-227; th227; (228)th; th-228; th228; (229)th; 229th; th-229; th229; (230)th; 230th; th-230; th230; (231)th; 231th; th-231; th231; (234)th; 234th; th-234; th234; (238)th; 238th; th-238; th238; (239)th; 239th; th-239; th239
NIH RePORTER
10/2017 | Search Criteria: Text Search: “thorium” OR “thoria” OR “thorianite” OR “thorotrast” OR “thortrast” OR “umbrathor” OR “radiothorium” OR “232th” OR “(232)th” OR “th-232” OR “th232” OR “(226)th” OR “226th” OR “th-226” OR “th226” OR “(227)th” OR “227th” OR “th-227” OR “th227” OR “228th” OR “(228)th” OR “th-228” OR “th228” OR “(229)th” OR “229th” OR “th-229” OR “th229” OR “(230)th” OR “230th” OR “th-230” OR “th230” OR “(231)th” OR “231th” OR “th-231” OR “th231” OR “(234)th” OR “234th” OR “th-234” OR “th234” OR “(238)th” OR “238th” OR “th-238” OR “th238” OR “(239)th” OR “239th” OR “th-239” OR “th239”; Search in: Projects AdminIC: All, Fiscal Year: Active Projects
Other | Identified throughout the assessment process

a Several versions of the TSCATS database were searched, as needed, by CASRN including TSCATS1 via Toxline (no date limit), TSCATS2 via https://yosemite.epa.gov/oppts/epatscat8.nsf/ReportSearch?OpenForm (date restricted by EPA receipt date), and TSCATS via CDAT (date restricted by ‘Mail Received Date Range’), as well as google for recent TSCA submissions.

The 2017 results were:

- Number of records identified from PubMed, TOXLINE, and TOXCENTER (after duplicate removal): 5,166
- Number of records identified from other strategies: 53
- Total number of records to undergo literature screening: 5,219

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on thorium:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 5,219
- Number of health effects studies considered relevant and moved to the next step: 99

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 99
- Number of health effect studies cited in the health effects section of the 1990 toxicological profile: 136
- Total number of health effect studies cited in the health effects sections of the updated profile: 169
- Number of new studies cited in the updated profile: 33

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 June 2017 Literature Search Results and Screen for Thorium