# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

## Thorium Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Thorium
CAS Numbers: | 7440-29-1
Date: | October 1990
| June 2017—Updated literature search
Profile Status: | Final draft
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL.

Rationale for Not Deriving an MRL: No exposure-response data are available for humans. Studies in laboratory animals were limited to a series of studies conducted by Hall et al. (1951) examining the toxicity of thorium nitrate and thorium dioxide in dogs and rabbits exposed for approximately 2 weeks. Hematological effects were reported in dogs; however, the two studies found different effects. In dogs exposed to thorium nitrate (4.0 nCi/m^3^ as thorium), leukocytosis, abnormal lymphocytes, and hypersegmented polymonorphonuclear granulocytes were observed; no alterations in erythrocyte counts were observed. In contrast, exposure to 4.8 nCi/m^3^ as thorium dioxide resulted in decreases in erythrocyte counts, increased percentage of lymphocytes, and nonfilamented polymorphonuclear neutrophils. No hematological effects were observed in rabbits exposed to 3.5 or 3.8 nCi/m^3^ as thorium nitrate. The studies also conducted histological alterations in numerous studies including the lungs and reported no alterations. The Hall et al. (1951) studies were not considered suitable as the basis of an MRL due to the lack of control groups, small number of animals tested in the dog studies (4/group), testing only one exposure level, inadequate reporting of results, and the inconsistency of the findings across studies.

Agency Contacts (Chemical Managers): Sam Keith

## Thorium Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Thorium
CAS Numbers: | 7440-29-1
Date: | October 1990
| June 2017—Updated literature search
Profile Status: | Final draft
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL.

Rationale for Not Deriving an MRL: No exposure-response data are available for humans. Hall et al. (1951) examined the intermediate-duration toxicity of thorium tetrafluoride in dogs and thorium oxalate in dogs and rabbits. Decreased erythrocyte counts were observed in dogs exposed to 0.9 nCi/m^3^ as thorium tetrafluoride and 1.4 nCi/m^3^ as thorium oxalate; the dogs received 51 and 45 exposures (6 hours/day, 5 days/week), respectively. No hematological effects were observed in the rabbits exposed to 1.6 nCi/m^3^ for 21 exposures. The investigators reported no alterations in histopathological examinations of numerous tissues (including the lungs). The Hall et al. (1951) studies were not considered suitable as the basis of an MRL due to a number of study limitations, including the small number of animals per group (four dogs per compound; histopathology examination conducted in two dogs/compound), no control group, only testing one concentration per compound, and inadequate reporting of results.

Agency Contacts (Chemical Managers): Sam Keith

## Thorium Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Thorium
CAS Numbers: | 7440-29-1
Date: | October 1990
| June 2017—Updated literature search
Profile Status: | Final draft
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL.

Rationale for Not Deriving an MRL: No exposure-response data are available for humans. In the only available animal studies, no thorium exposure-related adverse effects were observed in rats, rabbits, guinea pigs, or dogs repeatedly exposed to thorium dioxide by inhalation at 0.55 nCi/m^3^ (the only exposure level tested) for 12–14 months (Hodge et al. 1960).

Agency Contacts (Chemical Managers): Sam Keith

## Thorium Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Thorium
CAS Numbers: | 7440-29-1
Date: | October 1990
| June 2017—Updated literature search
Profile Status: | Final draft
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL.

Rationale for Not Deriving an MRL: No human data are available. The only available acute-duration oral study reported only a NOAEL of 84 nCi/kg and the death of 4/20 mice administered thorium nitrate at 110 nCi/kg once by gavage.

Agency Contacts (Chemical Managers): Sam Keith

## Thorium Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Thorium
CAS Numbers: | 7440-29-1
Date: | October 1990
| June 2017—Updated literature search
Profile Status: | Final draft
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL.

Rationale for Not Deriving an MRL: No human data are available. Two intermediate-duration oral studies were located. In one study, the only adverse treatment-related effect among rats administered thorium nitrate in the food for 105–131 days at 130 nCi/kg/day decreased body weight gain; however, this was attributed to decreased food intake (Downs et al. 1959). In the other study, 10/20 mice died during a 4-month exposure to thorium nitrate in the drinking water at an estimated dose of 12 nCi/kg/day (the only exposure level tested); there were no other reported effects (Patrick and Cross 1948).

Agency Contacts (Chemical Managers): Sam Keith

## Thorium Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Thorium
CAS Numbers: | 7440-29-1
Date: | October 1990
| June 2017—Updated literature search
Profile Status: | Final draft
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL.

Rationale for Not Deriving an MRL: No chronic-duration oral studies are available for humans or animals.

Agency Contacts (Chemical Managers): Sam Keith