# 7 REGULATIONS AND ADVISORIES

Because of its potential to cause adverse health effects in exposed people, a number of regulations and guidelines have been established for thallium by various national and state agencies. These values are summarized in Table 7-1.

TABLE 7-1 Regulations and Guidelines Applicable to Thallium and Compounds

Agency | | Description | Information | Reference
[underlined: NATIONAL]
Regulations:
a. | Air:
a. | OSHA | PEL TWA; (soluble compounds, as Tl) | 0.1 mg/m^3^ | OSHA 1989 (29 CFR 1910.1000) Table Z-1-A
b. | Water:
b. | EPA OWRS | General permits under NPDES | Yes | 40 CFR 122, Appendix D, Table II
b. | EPA OWRS | General pretreatment regulations for existing and new sources of pollution | Yes | 40 CFR 403
b. | EPA OWRS | Hazardous substance | | EPA 1989a (40 CFR 116)
b. | EPA OWRS | Thallium sulfate | Yes | EPA 1989a (40 CFR 116)
b. | EPA OWRS | Reportable quantity | | 40 CFR 117.3
b. | EPA OWRS | Thallium sulfate | 100 pounds | 40 CFR 117.3
c. | Nonspecific media:
c. | EPA OERR | Reportable quantity | | EPA 1989a (40 CFR 302.4)
c. | EPA OERR | Thallium | 1,000 pounds
c. | EPA OERR | Thallium (1) acetate | 100 pounds
c. | EPA OERR | Thallium (1) chloride | 100 pounds
c. | EPA OERR | Thallium (1) nitrate | 100 pounds
c. | EPA OERR | Thallic oxide | 100 pounds
c. | EPA OERR | Thallium (1) sulfate | 100 pounds
c. | EPA OERR | Thallium (1) carbonate | 100 pounds
c. | EPA OERR | Thallium selenite | 1,000 pounds
c. | EPA OERR | Extremely hazardous substance TPQ | | EPA 1987b (40 CFR 355)
c. | EPA OERR | Thallium sulfate | 100/10,000 pounds
c. | EPA OERR | Thallous chloride | 100/10,000 pounds
c. | EPA OERR | Thallous sulfate | 100/10,000 pounds
c. | EPA OERR | Thallous carbonate | 100/10,000 pounds
c. | EPA OERR | Thallous malonate | 100/10,000 pounds
c. | EPA OPP | Cancellation of all pesticide products containing thallium sulfate 03/09/72 | Yes | EPA 1985b
c. | EPA OSW | Hazardous waste constituent (Appendix VIII) (Thallium and Compounds) | Yes | EPA 1980c (40 CFR 261)
c. | EPA OSW | Groundwater monitoring list (Appendix IX) | Yes | EPA 1987c (40 CFR 264)
c. | EPA OSW | Land disposal restrictions | Yes | EPA 1988d, 1987d (40 CFR 264, 268)
c. | EPA OTS | Toxic chemical release reporting | Yes | EPA 1988c (40 CFR 372)
c. | EPA OTS | Health and safety data reporting rule | Yes | EPA 1988e (40 CFR 716)
Guidelines:
a. | Air:
a. | ACGIH | TLV TWA (soluble compounds as Tl) | 0.1 mg/m^3^ | ACGIH 1986
a. | NIOSH | IDLH (soluble compounds as Tl) | 20 mg/m^3^ | NIOSH 1985
b. | Water:
b. | EPA OURS | Ambient water quality criteria | | EPA 1980a
b. | EPA OURS | Ingesting water and organisms | 13 µg/L
b. | EPA OURS | Ingesting organisms only | 48 µg/L
c. | Other:
c. | EPA | Carcinogenic classification | Group D^a^ | EPA 1988a
c. | EPA | Thallium and salts
c. | EPA | RfD (oral) | | IRIS 1989
c. | EPA | Thallium (insoluble salts) | 7×10^−5^ mg/kg/day | EPA 1991
c. | EPA | Thallium (I) sulfate | 8×10^−5^ mg/kg/day
c. | EPA | Thallium (I) acetate | 9×10^−5^ mg/kg/day
c. | EPA | Thallium (I) chloride | 8×10^−5^ mg/kg/day
c. | EPA | Thallium (I) nitrate | 9×10^−5^ mg/kg/day
c. | EPA | Thallium (I) carbonate | 8×10^−5^ mg/kg/day
[underlined: STATE]
Regulations:
a. | Air: | Acceptable ambient air concentration | | NATICH 1989
a. | Connecticut | | 2.0 µg/m^3^ (8 hr)
a. | Florida (Tampa) | | 0.001 mg/m^3^ (8 hr)
a. | Kansas (Kansas City) | | 0.238 µg/m^3^ (1 yr)
a. | Nevada | | 0.002 mg/m^3^ (8 hr)
a. | New York | | 0.330 µg/m^3^ (1 yr)
a. | North Dakota | | 0.001 mg/m^3^ (8 hr)
a. | Pennsylvania (Philadelphia) | | 2.47 µg/m^3^ (1 yr)
a. | Pennsylvania (Philadelphia) | | 2.40 µg/m^3^ (annual)
a. | Virginia | | 1.60 µg/m^3^ (24 hr)
a. | Wisconsin | | 2.4 µg/m^3^ (24 hr)
b. | Water: | Drinking water | | FSTRAC 1988
b. | Kansas | | 13 µg/L
b. | Wisconsin | | 6.5 µg/L

a Group D = not classified as to human carcinogenicity. No evidence of carcinogenicity in at least two adequate animal tests in different species or in both adequate epidemiologic and animal studies.

ACGIH = American Conference of Governmental Industrial Hygienists; EPA = Environmental Protection Agency; IDLH = Immediately Dangerous to Life or Health Level; NIOSH = National Institute for Occupational Safety and Health; NPDES = National Pollutant Discharge Elimination System; OERR = Office of Emergency and Remedial Response; OPP = Office of Pesticide Products; OSHA = Occupational Safety and Health Administration; OSW = Office of Solid Wastes; OTS = Office of Toxic Substances; OWRS = Office of Water Regulations and Standards; PEL = Permissible Exposure Limit; TLV = Threshold Limit Value; TPQ = Threshold Planning Quantity; TWA = Time-Weighted Average