# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Table 3-1 lists common synonyms, trade names, and other pertinent identification information for thallium and a number of thallium compounds.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Table 3-2 lists important physical and chemical properties of thallium and selected thallium compounds.

TABLE 3-1 Chemical Identity of Thallium and Compounds^a^

Characteristic | Thallium | Thallium acetate | Thallium chloride | Thallium nitrate | Thallium oxide | Thallium sulfate
Synonyms | Ramor^b^ | Thallous acetate; thallium (1+) salt | Thallic chloride | Thallous nitrate; nitric acid, thallium (1+) salt | Thallic oxide | Thallous sulfate
Trade name | No data | No data | No data | No data | No data | No data
Chemical formula | Tl | TlC_2_H_3_O_2_ | TlCl_3_ | TlNO_3_ | Tl_2_O_3_ | Tl_2_SO_4_
Chemical structure | Not Applicable | Not Applicable | Not Applicable | Not Applicable | Not Applicable | Not Applicable
Identification numbers:
CAS Registry | 7440-28-0 | 563-68-8 | 13453-32-2 | 10102-45-1 | 1314-32-5 | 7416-18-6
NIOSH RTECS | XG3425000^c^ | AJ5425000^c^ | No data | XG5950000^c^ | XG2975000^c^ | No data
EPA Hazardous Waste | No data | V214^b^ | No data | V217^b^ | P113^b^ | No data
OHM/TADS | 7216925^b^ | 7217306^b^ | No data | No data | No data | No data
DOT/UN/NA/ | UN1707^b^ | UN1707^b^ | No data | UN2727^b^ | UN1707^b^ | No data
IMCO Shipping | IMCO 6.1^b^ | IMCO 6.1^b^ | No data | IMCO 6.1^b^ | IMCO 6.1^b^ | No data
HSDB | 4496^b^ | 855^b^ | No data | No data | 6055^b^ | No data
NCI | No data | No data | No data | No data | No data | No data

Characteristic | Thallium carbonate | Thallium bromide | Thallium iodide | Thallium fluoride
Synonyms | Thallous carbonate; carbonic acid; dithallium carbonate | Thallium monobromide; thallous bromide | Thallous iodide | Thallum monofluoride; Thallous fluoride
Trade name | No data | No data | No data | No data
Chemical formula | Tl_2_CO_3_ | TlBr | TlI | TlF
Chemical structure | Not Applicable | Not Applicable | Not Applicable | Not Applicable
Identification numbers:
CAS Registry | 6533-73-9 | 7789-40-0 | 7790-30-9 | 7789-27-7
NIOSH RTECS | XG4000000^c^ | XG3850000^c^ | XG5425000^c^ | XG4900000^c^
EPA Hazardous Waste | V215^b^ | No data | No data | No data
OHM/TADS | No data | No data | No data | No data
DOT/UN/NA/ | UN1707^b^ | No data | No data | No data
IMCO Shipping | IMC06.1^b^ | No data | No data | No data
NCI | No data | No data | No data | No data

a All information obtained from EPA 1988a, except where noted.

b HSDB 1989

c Sax 1984

CAS = Chemical Abstracts Service

DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code

EPA = Environmental Protection Agency

HSDB = Hazardous Substances Data Bank

NCI = National Cancer Institute

NIOSH = National Institute for Occupational Safety and Health

OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System

RTECS = Registry of Toxic Effects of Chemical Substances

TABLE 3-2 Physical and Chemical Properties of Thallium and Compounds^a^

Property | Thallium | Thallium acetate | Thallium chloride | Thallium nitrate | Thallium oxide | Thallium sulfate | Thallium carbonate | Thallium bromide | Thallium iodide | Thallium fluoride
Molecular weight | 204.38 | 263.43 | 310.74 | 266.39 | 456.76 | 504.82 | 468.78 | 284.29 | 331.29 | 223.38
Color | Blush-white | White | White^b^ | White^b^ | Colorless | Colorless | Colorless | Yellowish-white | Yellow; red (at 170°C) | Colorless
Physical state | Metal | Solid | Solid | Solid | Solid | Solid | Solid | Solid | Solid | Solid
Melting point | 303.5°C | 131°C | 25°C | 206°C^c^ | 717±5°C | 632°C | 273°C | 480°C | 440°C^c^ | 327°C
Boiling point | 1457±10°C | No data | Decomposes | 430°C^c^ | −20 at 875°C | Decomposes^c^ | No data | 815°C | 824°C^c^ | 655°C
Density at 20°C | 11.85 | 3.76 at 137°C | No data | 5.5^b^ | 9.65-10.19 at 21°C | 6.77 | 7.11 | 7.56 at 17.3°C | 7.29 | 8.23 at 4°C
Odor | Odorless^d^ | Odorless^d^ | No data | Odorless^d^ | No data | No data | No data | No data | No data | No data
Odor threshold:
Water | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Air | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Solubility:
Water at 20°C | Insoluble | Very soluble | Very soluble | 95.5 g/L | Insoluble | 48.7 g/L | 40.3 g/L; at 15.5°C | 0.5 g/L; at 25°C | 0.006 g/L | 786 g/L; at 15°C
Organic solvents | Soluble in nitric or sulfuric acid, | Very soluble in alcohol; insoluble in acetone | Soluble in alcohol and ether | Insoluble in alcohol; Soluble in acetone | Soluble in acids; Insoluble in alkalies | No data | Insoluble in alcohol, ether, and acetone | Soluble in alcohol, insoluble in acetone | Insoluble in alcohol, slightly soluble in nitric acid | Slightly soluble in alcohol
Partition coefficients:
Log octanol/water | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Log K_oc_ | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Vapor Pressure at 1000°C | 10 mmHg^c^ | No data | No data | No data | No data | No data | No data | 10 mmHg at 517°C^c^ | No data | No data
Henry’s law constant | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Autoignition temperature | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Flammability limits | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Conversion factors | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data

a All information obtained from Weast 1985, except where noted.

b Windholz 1983

c EPA 1988a

d HSDB 1989