# 8 REFERENCES

*Cited in text

*ACGIH. 1991. Threshold limit values and biological exposure indices for 1990-1991. American Conference of Governmental Industrial Hygienists. Cincinnati, OH, 35.
Aliev SR, Vakhabov AA, Sultanov MB. 1975. [Pharmacology of the alkaloid nitramine.] Dokl Akad Nauk Uzb 32:43–44. (Russian)
*Ames BN, McCann J, Yamasaki E. 1979. Methods for detecting carcinogens and mutagens with the Salmonella/mammalian-microsome mutagenicity test. In: Kilby BJ, Legator M, Nichols W, Ramel C, eds., Handbook of mutagenicity test procedures. New York: Elsevier Scientific Publishing Company, 1–17.
*Army. 1974. Munitions production products of potential concern as waterborne pollutants - phase II. Aberdeen, MD: U.S. Army Medical Bioengineering Research and Development Laboratory, 20–22.
Army. 1975. Toxicity to aquatic organisms and chemistry of nine selected waterborne pollutants from munitions manufacture - a literature evaluation. Washington, DC: U.S. Army Medical Research and Development Command. Document no. AD A010660.
*Army. 1976. Report on an in-depth pollution survey at Joliet Army Ammunition Plant. Dover, NJ: Picatinny Arsenal Manufacturing Technology Directorate. Document no. AD B011415.
*Army. 1977. The determination of tetryl and 2,3-, 2,4-, 2,5-, 2,6-, 3,4-, and 3,5- dinitrotoluene using high performance liquid chromatography. Washington, DC: U.S. Army Medical Research and Development Command. Document no. AD A042598
Army. 1978. Analysis of carbon versus resin. Aberdeen Proving Ground, MD: U.S. Army Chemical Systems Laboratory. Document no. AD A0538638
*Army. 1979. Evaluation of the environmental fate of munition compounds in soil. Frederick, MD: U.S. Army Medical Research and Development Command, Fort Detrick. Document no. AD A082874.
*Army. 1980. Milan Army Ammunition Plant contamination survey. Milan, TN: Milan Army Ammunition Plant. Document no. AD B053362.
*Army. 1981a. Identification of development of chemical analysis methods for plants and animal tissues. Aberdeen Proving Ground, MD: U.S. Army Toxic and Hazardous Materials Agency. Document no. AD A107346.
*Army. 1981b. Preliminary pollutant limit values for Alabama Army Ammunition Plant. Frederick, MD: U.S. Army Medical Research and Development Command, Fort Detrick. Document no. AD A104203.
*Army. 1981c. Environmental survey of Fort Wingate Depot Activity Gallup, New Mexico. Gallup, NM: Fort Wingate Army Depot Activity. Document no. AD B064866.
Army. 1982a. Contamination survey of Iowa Army Ammunition Plant. Aberdeen Proving Ground, MD: U.S. Army Toxic and Hazardous Materials Agency. Document no. AD B074331.
Army. 1982b. Geotechnical report for Iowa Army Ammunition Plant. Aberdeen Proving Ground, MD: U.S. Army Toxic and Hazardous Materials Agency. Document no. AD B074338.
*Army. 1982~. Iowa Army Ammunition Plant contamination report. Aberdeen Proving Ground, MD: U.S. Army Toxic and Hazardous Materials Agency. Document no. AD B074315.
Army. 1983a. HPLC analysis of SEX, HMX, TAX, RDX, and TNT in wastewater. Frederick, MD: U.S. Army Medical Research and Development Command, Fort Detrick. Document no. AD A127348.
Army. 1983b. Tertiary treatment of effluent from Holston AAP industrial liquid waste treatment facility: III. Ultraviolet radiation and ozone studies: TNT, RDX, HMX, TAX, and SEX. Frederick, MD: U.S. Army Medical Bioengineering Research and Development Laboratory, Fort Detrick. Document no. AD A137672.
Army. 1984a. Chemical characterization of dimethyl sulfoxide (DMSO) munitions recrystallization process samples. Frederick, MD: U.S. Army Medical Research and Development Command, Fort Detrick. Document no. AD A149103.
Army. 1984b. Development of novel decontamination techniques for explosive contaminated facilities. Aberdeen Proving Ground, MD: U.S. Army Toxic and Hazardous Materials Agency. Document no. AD POO4880.
*Army. 1984c. Tetryl fixation in water. Dover, NJ: U.S. Army Armament Research and Development Center. Document no. AD B083720.
*Army. 1984d. Database assessment of the health and environmental effects of munition production waste products. Frederick, MD: U.S. Army Medical Research and Development Command, Fort Detrick. Document no. AD A145417.
*Army. 1985. Development of optimum treatment system for wastewater lagoons - Phase II: Aqueous thermal decomposition laboratory testing. Aberdeen Proving Ground, MD: U.S. Army Toxic and Hazardous Materials Agency. Document no. AD B089592.
*Army. 1986a. Cornposting explosives/organics contaminated soils. Aberdeen Proving Ground, MD: U.S. Army Toxic and Hazardous Materials Agency. Document no. AD A169994.
*Army. 1986b. Demilitarization of conventional ordnance: Priorities for data-base assessments of environmental contaminants. Frederick, MD: U.S. Army Medical Research and Development Command, Fort Detrick. Document no. AD A182922.
*Army. 1986c. Application of solid sorbent collection techniques and high performance liquid chromatography with electrochemical detection to the analysis of explosives in water samples. Aberdeen Proving Ground, MD: U.S. Army Toxic and Hazardous Material Agency. Document no. DE87002973.
*Army. 1986d. Database assessment of the pollution control in the military explosives and propellants production industry. Frederick, MD: U.S. Army Medical Research and Development Command, Fort Detrick. Document no. AD ORNL-6202.
*Army. 1987a. Treatment alternatives for explosive-laden spent carbons. Aberdeen Proving Ground, MD: U.S. Army Toxic and Hazardous Materials Agency. Document no. AD A199506.
*Army. 1987b. Development of an analytical method for explosive residues in soil. Aberdeen Proving Ground, MD: U.S. Army Toxic and Hazardous Materials Agency. Document no. AD A183738.
Army. 1987c. Losses of explosives residues on disposable membrane filters. Aberdeen Proving Ground, MD: U.S. Army Toxic and Hazardous Materials Agency. Document no. AD A180889.
*Army. 1987d. Conventional weapons demilitarization: A health and environmental effects data base assessment: Explosives and their co-contaminants. Frederick, MD: U.S. Army Medical Research and Development Command, Fort Detrick. Document no. AD A220588.
*Army. 1988. Improved RP-HPLC method for determining nitroaromatics and nitramines in water. Aberdeen Proving Ground, MD: U.S. Army Toxic and Hazardous Materials Agency. Document no. AD A203306.
*Army. 1989a. Validation of a sorbent tube/high performance liquid chromatographic procedure for the determination of eight explosives in water. Aberdeen Proving Ground, MD: U.S. Army Toxic and Hazardous Materials Agency. Document no. AD A210777.
*Army. 1989b. Organic explosives and related compounds: Environmental and health considerations. Washington, DC: U.S. Army Corps of Engineers. Document no. AD A210554.
*Army. 1990a. Development of an analytical method for the determination of explosive residues in soil: Collaborative test results and final performance evaluation. Aberdeen Proving Ground, MD: U.S. Army Toxic and Hazardous Materials Agency. Document no. AD A2130003.
*Army. 1990b. Phase I results report: Remedial investigation, manufacturing area, Joliet Army Ammunition Plant, Illinois. Vol. 1 of 2 (Final). Aberdeen Proving Ground, MD: U.S. Army Toxic and Hazardous Materials Agency. Document no. AD B148444.
*Atkinson R. 1987. A structure-activity relationship for the estimation of rate constants for the gas-phase reactions of OH radicals with organic compounds. International Journal of Chemical Kinetics 19:799–799.
*ATSDR. 1987. Health assessment for Alabama Army Ammunition Plant, Talladega County, Alabama, region 4. Atlanta, GA: Agency for Toxic Substances and Disease Registry. CERCLIS no. AL6210020008.
ATSDR. 1989a. Health assessment for Comhusker Army Ammunition Plant, Grand Island, Nebraska, region 7. Atlanta, GA: Agency for Toxic Substances and Disease Registry. CERCLIS no. NE2213820234.
ATSDR. 1989b. Health assessment for Louisiana Army Ammunition Plant, Shreveport, Webster County, Louisiana, region 6. Atlanta, GA: Agency for Toxic Substances and Disease Registry. CERCLIS no. LA0213820533.
ATSDR. 1989c. Health assessment for Milan Army Ammunition Plant, Milan, Carol, and Gibson Counties, Tennessee, region 4. Atlanta, GA: Agency for Toxic Substances and Disease Registry. CERCLIS no. TND210030582.
ATSDR. 1989d. Health assessment for Savanna Army Depot, Savanna, Carroll County, Illinois, region 5. Atlanta, GA: Agency for Toxic Substances and Disease Registry. CERCLIS no. ILO213820376.
ATSDR. 1989e. Health assessment for Umatilla Army Depot, Hermiston, Oregon, region 10. Atlanta, GA: Agency for Toxic Substances and Disease Registry. CERCLIS no. OR6213820917.
*ATSDR/CDC. 1990. Subcommittee report on biological indicators of organ damagk. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention, Atlanta, GA.
*Bain WA, Thomson GH. 1954. Pilot trial of an antihistaminic drug in the control of “tetryl” dermatitis. Br J Ind Med 11:25–25.13140814
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–471.3222488
*Bauer CF, Koza SM, Jenkins TF. 1990. Liquid chromatographic method for determination of explosives residues in soil: Collaborative study. J Assoc Off Anal Chem 73:541–541.
*Beard RR, Noe JT. 1981. Aromatic nitro and amino compounds. In: Clayton GD, Clayton FE, eds. Patty’s industrial hygiene and toxicology, Vol IIa, 3rd ed. New York, NY: John Wiley and Sons, 2413–2489.
*Belkin F, Bishop RW, Sheely MV. 1985. Analysis of explosives in water by capillary gas chromatography. J Chromatogr Sci 23:532–532.
*Berberich DW, Yost RA, Fetterolf DD. 1988. Analysis of explosives by liquid chromatography/thermospray/mass spectrometry. J Forensic Sci 33:946–946.
*Bergman BB. 1952. Tetryl toxicity: A summary of ten years’ experience. AMA Archives of Industrial Hygiene 5:10–10.
*Bhasu VCJ, Chaudhri MM, Housden J. 1991. Rapid-mass spectrometric analysis of fragments of trinitrotoluene, picric acid, and tetryl generated by laser irradiation. Journal of Materials Science 2612199–2207.
*Bongiovanni R, Podolak GE, Clark LD, . 1984. Analysis of trace amounts of six selected poly-nitro (explosive) compounds in soils. Am Ind Hyg Assoc J 45:222–222.
*Brabham VW. 1943. Tetryl illness in munition plants. J S C Med Assoc 39:93–93.
Bratin K, Kissinger PT, Briner RC, . 1981. Determination of nitro aromatic, nitramine, and nitrate ester explosive compounds in explosive mixtures, and gunshot residue by liquid chromatography and reductive electrochemical detection. Anal Chim Acta 130:295–295.
*Brownlie IA, Cumming WM. 1946. Tetryl dermatitis: The interaction of aromatic nitro-compounds with amino-acids and proteins. Biochem J 40:640–640.
Burns DT, Eltayeb MAZ, Flockhart BD. 1987. Identification and determination of aromatic nitro-compounds by electron spin resonance spectrometry. Anal Chim Acta 200:481–481.
Burrows EP, Brueggemann EE. 1985. Reversed-phase gradient high-performance liquid chromatography of nitramine munitions and characterization of munitions process samples by gas chromatography-mass spectrometry. J Chromatogr 329:285–285.
Burrows WD, Chyrek RH, Noss CI, . 1984. Treatment for removal of munition chemicals from Army industrial wastewaters. Toxic Hazard Wastes Proc Mid-At1 Ind Waste Conf 16th, 331–342.
Cantu AA, Washington WD, Strobe1 RA, . 1983. Evaluation of FTIR as a detector for the HPLC analysis of explosives. In: Proceedings of the International Symposium on the analysis and detection of explosives, FBI Academy, Quantico, VA, March 29-31, 1983. Washington, DC: U.S. Department of Justice, Federal Bureau of Investigation, 349–363.
*CELDS. 1991. Computer-Aided Environmental Legislative Data Systems. University of Illinois, Urbana, IL. June 20, 1991.
*CEQ. 1970. Ocean dumping: A national policy. Council on Environmental Quality, Government Printing Office. Washington, DC.
Challis BC, Li BF. 1982. Formation of n-nitroamines by photolysis. IARC Sci Pub1 41:31–31.
*Cripps L. 1917. The properties of tetryl (as affecting the human system). Br J Dermat 29:3–3.
*Daniele E. 1964. Blood clotting alterations in chronic laboratory tetryl poisoning. Folia Medica 8:767–776. (Italian)
DODCA. 1987. A comparative assessment of U.S. and U.K. explosives qualified as replacements for tetryl. Report MRL-R-1094. Melbourne, Victoria, Australia: Department of Defence of the Commonwealth of Australia, Defence Science and Technology Organization, Materials Research Laboratories. Document no. AD A191928.
*DOT. 1989a. List of hazardous substances and reportable quantities. Department of Transportation. Code of Federal Regulations. 49 CFR 172.101.
*DOT. 1989b. Hazardous materials table and hazardous material communications regulations. Department of Transportation. Federal Register 54:39501–39501.
*Douse JMF. 1981. Trace analysis of explosives at the low picogram level by silica capillary column gas-liquid chromatography with electron-capture detection. J Chromatogr 208:83–83.
*Douse JMF. 1982. Trace analysis of explosives in hand-swab extracts using Amberlite XAD-7, porous beads, silica capillary-column gas chromatography with electron-capture detection and thin-layer chromatography. J Chromatogr 234:415–415.
*Douse JMF. 1985. Trace analysis of explosives at the low nanogram level in handswab extracts using columns of Amberlite XAD-7, porous polymer beads and silica capillary column gas chromatography with thermal energy analysis and electron-capture detection. J Chromatogr 328:155–155.
Doyle RC, Isbister JD, Forgacs TW, . 1985. Composting explosives contaminated sediments. In: Proceedings of the American Defense Preparedness Association, 14th Environmental Systems Symposium, October 23-25, 1986. Baltimore, MD: American Defense Preparedness Association, 40–44.
*Eddy JH. 1943. Some toxic reactions of common explosives. Industrial Medicine 12:483–483.
*Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15:30–30.
*Engelhardt H, Meister J, Kolla P. 1993. Optimisation of post-column reaction detector for HPLC of explosives. Chromatographia 35: 5–12
EPA. 1976. Investigation of selected potential environmental contaminants: Nitroaromatics. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA-560/2-76-010.
EPA. 1988a. Hazardous substances priority list, toxicological profiles, second list. U.S. Environmental Protection Agency. Federal Register 53(203):41280–41285.
EPA. 1988b. U.S. Environmental Protection Agency. Code of Federal Regulations. 29 CFR 1910.20.
EPA. 1989. Toxicological profile for tetryl. Washington, DC.: U.S. Environmental Protection Agency, Criteria and Standards Division, Office of Drinking Water.
EPA. 1990a. Interim methods for development of inhalation reference doses. U.S. Environmental Protection Agency. EPA/600/8-90/066A.
*EPA. 1990b. Lists of hazardous wastes. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.32, Subpart D.
EPA. 1990~. Health and environmental effects document for trinitrophenylmethylnitramine, draft, October 1990. Cincinnati, OH: Environmental Criteria and Assessment Office, U.S. Environmental Protection Agency. ECAO-CIN-G091.
*Fati S, Daniele E. 1965. Histopathological findings in chronic laboratory poisoning. Folia Medica 1:269–276. (Italian)
FEDRIP. 1991. Federal Research in Progress. Dialog Information Service, Inc. June 1991.
*Feltes J, Levsen K. 1989. Reversed phase high-performance liquid chromatographic determination with photodiode-array detection of nitroaromatics from former ammunition plants in surface waters. Journal of High Resolution Chromatography 12:613–613.
Feltes J, Levsen K. 1990. Gas chromatographic and mass spectrometric determination of nitroaromatics in water. J Chromatogr 51821–40.
*Fine DH, Yu WC, Goff EU. 1983. Applications of the nitro/nitroso specific detector to explosive residue analysis. In: Proceedings of the International Symposium on the analysis and detection of explosives, FBI Academy, Quantico, VA, March 29-31, 1983. Washington, DC: U.S. Department of Justice, Federal Bureau of Investigation, 169–179.
*Fine DH, Yu WC, Goff EU, . 1984. Picogram analyses of explosive residues using the thermal energy analyzer (TEA). J Forensic Sci 29:732–732.
*Fischer CN, Murdock HD. 1946. Tetryl exposure: Analysis of four years of medical experience with tetryl. Industrial Medicine 15:428–428.
Fisco W. 1975. Portable explosives identification kit for field use. J Forensic Sci 20:141–141.1117263
Foussereau J, Benezra C, Maibach HI, . 1982. Army arsenals. In: W.B. Saunders Company. Occupational contact dermatitis, clinical and chemical aspects. Philadelphia, PA: W.B. Saunders Company, 171–176.
Gartz JEF. 1981. [Studies on the thin-layer chromatographic detection of nitramines and nitric acid esters.] Pharmazie 36:784. (German)
*Gel1 PGH. 1944. Sensitization to “tetryl.” Br J Exp Path01 25:174–174.
*Gibbs TR, Popolato A, eds. 1980. LASL explosive property data. Berkeley, CA: University of California Press, 163–171.
*Gob CL, 1984. Allergic contact dermatitis from tetryl and trinitrotoluene. Contact Dermatitis 10:108.6232089
Goh CL, Rajan VS. 1983. Contact sensitivity to trinitrotoluene. Contact Dermatitis 9:433–433.
Grant WM. 1986. Toxicology of the eye. 3rd edition. Springfield, IL: CC Thomas, Publisher, 895.
*Griest WH, Guzman C, Dekker M. 1989. Packed-column supercritical fluid chromatographic separation of highly explosive compounds. J Chromatogr 467:423–423.
*Griswold DP, Casey AE, Weisburger EK, . 1968. The carcinogenicity of multiple intragastric doses of aromatic and heterocyclic nitro or amino derivatives in young female Sprague-Dawley rats. Cancer Res 28:924–924.5652305
*Guarino A, Zambrano A. 1957. Histopathological research in subacute experimental intoxication by tetryl. Folia Medica 40:389–396. [Italian]
Hamilton A, Hardy HL. 1974. Industrial toxicology. 3rd edition. Acton, MA: Publishing Sciences Group, Inc., 308.
*Hardy HL, Maloof CC. 1950. Evidence of systemic effect of tetryl. Archives of Industrial Hygiene 1:545–545.
*Harvey SD, Fellows RJ, Cambell JA, . 1992. Determination of the explosive 2,4,6-trinitrophenylmethylnitramine (tetryl) and its transformation products in soil. J Chromatogr 605: 227–240
*Harvey SD, Fellows RJ, Cataldo DA, . 1993. Analysis of the explosive 2,4,6-trinitrophenylmethylnitramine (tetryl) in bush bean plants. J Chromatogr 630: 167–177
*Hatch HS, Probst EW. 1945. Effects of tetryl on the lungs. Industrial Medicine 14:189–189.
*HAZDAT. 1994. Hazardous Materials Data Base. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA.
Hess TL, Guidry LJ, Sibley SD. 1975. An automated system for analysis of nitro-compounds in water. Bull Environ Contam Toxicol 13:579–579.1148413
*Hilton J, Swanston CN. 1941. Clinical manifestations of tetryl and trinitrotoluene. Br Med J 2:509–509.20783901
Hine J, Mookerjee PK. 1975. The intrinsic hydrophilic character of organic compounds: Correlations in terms of structural contributions. J Org Chem 40:292–292.
*Hoffsommer JC, Rosen JM. 1972. Analysis of explosives in sea water. Bull Environ Contam Toxicol 7:177–177.
*Hoffsommer JC, Rosen JM. 1973. Hydrolysis of explosives in sea water. Bull Environ Contam Toxicol 10:78–78.4749300
*HSDB. 1994. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*Jenkins TF, Walsh ME. 1994. Instability of tetryl to Soxhlet extraction. J Chromatogr 662: 178–184
*Jenkins TF, Walsh ME, Schumacher PW, . 1989. Liquid chromatographic method for determination of extractable nitroaromatic and nitramine residues in soil. J Assoc Off Anal Chem 72:890–890.
Kaplan MA, Zitrin S. 1977. Identification of post-explosion residues. J Assoc Off Anal Chem 60:619–619.
*Kawai A, Goto S, Matsumoto Y, . 1987. [Mutagenicity of aliphatic and aromatic nitro compounds - industrial materials and related compounds.] Japanese Journal of Industrial Health 29:34–54. (Japanese)3613249
*Kayser EG, Burlinson NE. 1988. Migration of explosives in soil: Analysis of RDX, TNT, tetryl from a carbon-14 lysimeter study. J Energetic Material 6:45–45.
Keefer LK, Lunn G. 1985. Reductive destruction of nitrosamines, hydrazines, nitramines, azo- and azoxy-compounds. National Institute of Health, U.S. patent no. 4534154.
Ketel WB, Hughes JR. 1972. Toxic encephalopathy with seizures secondary to ingestion of an explosive material composition C-4: A clinical and electroencephalographic study. Electroencephalogr Clin Neurophysiol 33:352–352.
*Kirk-Othmer. 1980. Encyclopedia of chemical technology. Volume 9. New York, NY: John Wiley 8z Sons, 585.
*Kleiboehmer W, Cammann K, Robert J, . 1993. Determination of explosive residues in soils by micellar electrokinetic capillary chromatography and high-performance liquid chromatography. J Chromatogr 638: 349–356
Krogsrud S, Lang KT. 1989. USA Army toxic and hazardous materials agency monoclonal antibody technology program [Abstract]. Abstract Papers of the American Chemical Society 198:AGR0 58.
*Krogsrud S, Lang KT. 1990. Monoclonal antibody technology program. In: Van Emon JM, Mumma RO, eds. Immunochemical methods for environmental analysis. American Chemical Society Symposium Series No. 442, 1987 National Meeting, Miami Beach, Florida. Washington, DC: American Chemical Society, 21–26.
Krull IS, Ding XD, Selavka C, . 1984. Explosives and other nitro compounds determined by liquid chromatography with photolysis-electrochemical detection. Methodological Surveys in Biochemistry and Analysis 14:365–365.
*Levsen K, Mussmann P, Berger E, . 1993. Analysis of nitroaromatics and nitramines in ammunition waste water and in aqueous samples from.former ammunition plants and other military sites. Acta Hydrochim Hydrobiol 21:153–153.
*Lide DR. 1991. CRC handbook of chemistry and physics. 71st edition. Ann Arbor, MI: CRC Press, 3–43.
Lindley CRC, Calvert JG, Shaw JH. 1979. Rate studies of the reactions of the dimethylamidogen radical with oxygen, nitric oxide and nitrogen oxide (N02). Chemical Physics Letters 67:57–57.
*Lloyd JBF. 1983a. Clean-up procedures for the examination of swabs for explosive traces by high-performance liquid chromatography with electrochemical detection at a pendent mercury drop electrode. J Chromatogr 261:391–391.
*Lloyd JBF. 1983b. High performance liquid chromatography of organic explosives components with electrochemical detection at a pendant mercury drop electrode. J Chromatogr 257:227–227.
Lloyd JBF. 1985a. Adsorption characteristics of organic explosives compounds on adsorbents typically used in clean-up and related trace analysis techniques. J Chromatogr 328:145–145.
Lloyd JBF. 1985b. Microcolumn clean-up and recovery techniques for organic explosives compounds and for propellants traces in firearms discharge residues. J Chromatogr 330:121–121.
*Lyman WJ, Reehl WF, Rosenblatt DH. 1982. Handbook of chemical property estimation methods. New York, NY: McGraw-Hill, 4–9, 5–10, 15–15.
*Lyter AH II. 1983. A high performance liquid chromatographic (HPLC) study of seven common explosive materials. J Forensic Sci 28:446–446.
*Mabey WR, Baraze A, Mill T. 1983. Photolysis of nitroaromatic compounds. Chemosphere 12:3–3.
*Mackison FW, Stricoff RS, Partridge LJ. 1978. NIOSH/OSHA occupational health guidelines for chemical hazards. Cincinnati, OH: Department of Health and Human Services, National Institute for Occupational Safety and Health. DHHS(NIOSH) publication, 1,3.
*Margalit Y, Abramovich-Bar S, Bamberger Y, . 1986. Analysis of explosives by nuclear magnetic resonance spectrometry. J Energetic Material 4:363–363.
Mark HF, Othmer DF, Overberger CF, . 1980. Encyclopedia of chemical technology. Third edition, volume 9. New York, NY: John Wiley & Sons.
Mark HF, Othmer DF, Overberger CF, . 1985. Kirk-Othmer concise encyclopedia of chemical technology. New York, NY: Wiley Interscience Publications, John Wiley & Sons.
*McConnell WJ, Flinn RH, Brandt AD. 1946. Occupational diseases in government-owned ordnance explosives plants. Occup Med 1:551–551.20992679
*McGregor DB, Riach CG, Hastwell RM, . 1980. Genotoxic activity in microorganisms of tetryl, 1,3-dinitrobenzene and 1,3,5-trinitrobenzene. Environ Mutagen 2:531–531.7030731
*Merck Index. 1989. The Merck index: An encyclopedia of chemicals, drugs, and biologicals. Budavari S (ed.). Rahway, NJ: Merck & Co., Inc., 6491.
*Meyer R, ed. 1987. Explosives. 3rd ed. New York, NY: VCH Weinhein, ~340–341.
Miller HH, Crook MV, Spigarelli JL. 1983. Development of sampling and preservation techniques to retard chemical and biological changes in water samples. Issue DRXTH-TE-CR-82182, 231.
*Murray HML, Prunster RW, Anderson RD. 1944. The incidence of tetryl dermatitis or “C.E.” rash: A review of investigations carried out in Australian fuse-filling factories. Med J Aust 1:104–104.
Nakamura J. 1977. [Gas chromatographic detection and determination of the base charge in a blasting cap fragment.] Kagaku Keisatsu Kenkyusho Hokoku 30:259–262. (Japanese)
*NAS/NRC. 1989. Biological markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
*NATICH. 1991. National Air Toxics Information Clearinghouse. Data base report on state, local, and EPA air toxics activities. U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards, Washington, DC. August 13, 1991.
*Navy. 1972. Analysis of explosives in sea water and in ocean floor sediment and fauna. Silver Spring, MD: Naval Ordnance Laboratory. Document no. AD 757778.
*Navy. 1982. Migration of explosives in soil. Report no. NSWC TR 82-566. Silver Spring, MD: Naval Surface Weapons Center, White Oak. Document no. AD A135417.
Navy. 1984a. Indicator tubes for the detection of explosives. Report no. NWC TP 6569. China Lake, CA: Naval Weapons Center. Document no. AD A152385.
*Navy. 1984b. Kinetics of hydrolysis and products of hydrolysis and photolysis of tetryl. Silver Spring, MD: Naval Surface Weapons Center, White Oak. Document no. AD A153144.
*NIOSH. 1977. Sampling procedures. In: NIOSH manual of analytical methods. 2nd edition. Washington D.C.: U.S. Department of Health, Education, Welfare, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, 3:S225–1.
*NIOSH. 1990. Pocket guide to chemical hazards. Washington, D.C.: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, U.S. Government Printing Office, 212–213.
Noro L. 1941. Untersuchungen uber die trotyl-, tetryl- und knallquecksilber- vergiftungen bei den arbeiten der munitionsfabriken Finnlands. Acta Med Stand 120:1–95. (German)
*NREPC. 1986. Proposed regulation. Frankfort, KY: Department for Environmental Protection, Natural Resources and Environmental Protection Cabinet. 401 KAR 63:022.
*OSHA. 1989a. Occupational safety and health standards: Toxic and hazardous substances. U.S. Department of Labor, Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000.
*OSHA. 1989b. Air contaminants. U.S. Department of Labor, Occupational Safety and Health Administration. Federal Register 54:2920–2920.
*OTA. 1990. Neurotoxicity: Identifying and controlling poisons of the nervous system. Office of Technology Assessment, Washington, DC. OTA-BA-438.
*Parker RG, McOwen JM, Cherolis JA. 1975. Analysis of explosives and explosive residues: Part 2. Thin layer chromatography. J Forensci Sci 20:254–254.
*Parmeggiani L, Bartalini E, Sassi C, . 1956. Tetryl occupational diseases: Experimental investigation and prevention. Med Lavoro 47:293–313. [Italian]13347566
Parmeggiani L, ed. 1983. Encyclopedia of occupational health and safety. Geneva, Switzerland: International Labour Office, 2165–2166.
Pesce-Rodriquez RA, Fifer RA. 1990. Photoacoustic FTIR investigation of a nitramine propellant system [Abstract]. In: 41st Pittsburgh Conference and Exposition on analytical chemistry and applied spectroscopy, Pittsburgh, PA, March 5-9, 1990. Aberdeen Proving Ground, MD: U.S. Army Ballistic Research Laboratory, 5–9.
Petrosyan VA, Frolovskii VA. 1989. Electrochemical generation of n-nitramine ions upon the reduction of n-nitramines. Bulletin of the Academy of Sciences of the USSR Division of Chemical Science 382439.
*Probst EW, Mund MH, Lewis LD. 1944. Effects of tetryl. JAMA 126:424–424.
Roth M, Murphy JM Jr. 1978. Correlation of oxygen demand and total organic carbon tests on wastewaters from ammunition plants. Proc Ind Waste Conf 32:674–674.
*Ruxton WL. 1917. An investigation into the cause and prevention of industrial diseases due to tetryl. Br J Dermatol 29:18–18.
*Sax NI, Lewis RJ Sr. 1987. Hawley’s condensed chemical dictionary. 11th edition. New York, NY: Van Nostrand Reinhold Co., 1141.
Sax NI, Lewis RJ Sr. 1989. Dangerous properties of industrial materials. 7th edition, volume III. New York, NY: Van Nostrand Reinhold Co.
*Schwartz L. 1944. Dermatitis from explosives. JAMA 125:186–186.
Seidell A. 1941. Solubilities of organic compounds. New York, NY: Van Nostrand Reinhold Co.
Selavka CM, Krull IS. 1986. Liquid chromatography with photolysis - electrochemical detection for nitro-based high explosives and water gel formulation sensitizers. J Energetic Material 4:273–273.
Silver ALL. 1938. The treatment and prevention of industrial diseases in filling factories. J R Army Med Corps 71:87–87.
*Smith E. 1916. The prevention, symptoms, and treatment of tetryl dermatitis. Br Med J 1:618.
Solomonovici A. 1986. Identification of explosives in Soviet weapons. J Energetic Material 4:315–315.
*Strobe1 RA, Tontarski RE. 1983. Organic solvent extracts of explosive debris: Clean-up procedures using bonded phase sorbents. In: Proceedings of the International Symposium on the analysis and detection of explosives, FBI Academy, Quantico, VA, March 29-31, 1983. Washington, DC: U.S. Department of Justice, Federal Bureau of Investigation, 67–70.
Sullivan RJ, Watson GW. 1983. Sampling of explosives with multiple, portable preconcentrating cartridges. In: Proceedings of the International Symposium on the analysis and detection of explosives, FBI Academy, Quantico, VA, March 29-31, 1983. Washington, DC: U.S. Department of Justice, Federal Bureau of Investigation, 431–440.
*Swarm RL, Laskowski DA, McCall PJ, . 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Residue Reviews 85:16–16.
*Tamiri T, Zitrin S. 1986. Capillary column gas chromatography/mass spectrometry of explosives. Journal of Energetic Material 4:215–215.
*TRI. 1993. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*Troup HB. 1946. Clinical effects of tetryl (CE powder). Br J Ind Med 3:20–20.20983525
Urbanski T. 1983. Chemistry and technology of explosives. Volume 3. New York, NY: Pergamon Press, 40–62.
Volk F. 1977. [Study on the fumes produced by the detonation of various explosives.] Explosifs 30:72–80. (German)
*Wells HG, Lewis JH, Sansum WD, . 1920. Observations of the toxicity of tetranitromethylaniline (tetryl), tetranitroxylene (T.N.X), tetranitraniline (T.N.A), dinitrodichlorobenzene (parazol), and metanitraniline. Journal of Industrial Hygiene 2: 247–252.
Whong WZ, Edwards GS. 1984. Genotoxic activity of nitroaromatic explosives and related compounds in Salmonella typhimurium. Mutat Res 136:209–209.6377057
*Whong WZ, Speciner ND, Edwards GS. 1980a. Mutagenic activity of tetryl, a nitroaromatic explosive, in 3 microbial test systems. Toxicol Lett (Amst) 5:11–11.
Whong WZ, Speciner ND, Edwards GS. 1980b. Mutagenicity of polynitroaromatic explosives in microbial test systems. Proc Am Assoc Cancer Res 21:195.
Williams RT, Ziegenfuss PS, Mohrman GB, . 1989. Composting of explosives and propellant contaminated sediments. Hazard Ind Waste 21:599–599.
*Witkowski LJ, Fischer CN, Murdock HD. 1942. Industrial illness due to tetryl. JAMA i19:1406–1409.
Yinon J. 1983. Analysis of explosives by LC/MS. In: Proceedings of the International Symposium on the analysis and detection of explosives, FBI Academy, Quantico, VA, March 29-31, 1983. Washington, DC: U.S. Department of Justice, Federal Bureau of Investigation, 227–234.
*Yinon J, Laschever M. 1982. Direct-injection chemical ionization mass spectrometry of explosives in water. European Journal of Mass Spectrometry in Biochemistry, Medicine, and Environmental Research 2:101–101.
Yoshida M, Sunaga M, Hara I. 1990. Selenium status in workers handling aromatic nitro-amino compounds in a chemical factory. J Toxicol Environ Health 31: 1–10.2213918
*Zambrano A, Mandovano S. 1956. Urinary excretion of picric acid, picramic acid, and of sulfoconjugation products in experimental tetryl poisoning. Folia Med. (Naples) 39: 162–171. (Italian)
*Zitrin S, Yinon J. 1976. Chemical ionization mass spectrometry of explosives. Advances in Mass Spectrometry in Biochemistry and Medicine 1:369–369.