# 7 REGULATIONS AND ADVISORIES

The international, national, and state regulations and guidelines regarding tetryl in air, water, and other media are summarized in Table 7-1.

ATSDR has not derived MRLs for tetryl because of the lack of reliable human or animal studies which identify levels of exposure associated with adverse health effects. In addition, EPA has not verified a reference dose (RfD) for oral exposure or a reference concentration (RfC) for inhalation exposure to tetryl.

The transportation of explosives including tetryl must be in accordance with the Department of Transportation hazardous material regulations (49 CFR 171-190) and the motor carrier safety regulations (49 CFR 390-398). Numerous states have established regulations on explosives for air quality control, solid waste disposal, storage, manufacture, and use.

TABLE 7-1 Regulations and Guidelines Applicable to Tetryl

Agency | Description | Information | Reference
[underlined: NATIONAL]
Regulations:
a. Air:
OSHA | PEL TWA (skin designation) | 1.5 mg/m^3^ | OSHA 1989a; (29 CFR 1910.1000); OSHA 1989b
b. Other
DOT | Class A explosive (high explosive domestic transportation limited to road and water)(cargo only, in magazines) | Yes | DOT 1989a; (49 CFR 172.101); DOT 1989b
Guidelines:
a. Air
ACGIH | TLVTWA | 1.5 mg/m^3^ | ACGIH 1991
NIOSH | REL (10-hour TWA) (skin designation) | 1.5 mg/m^3^ | NIOSH 1990
[underlined: STATE]
Regulations and Guidelines:
a. Air:
| Acceptable Ambient Air Concentrations | | NATICH 1991
CT | 8 hr avg. time | 30.0 μg/m^3^
FL-Pinellas | 8 hr avg. time | 15.0 μg/m^3^
FL-Pinellas | 8 hr avg. time | 3.6 μg/m^3^
MD | | 0.00
ND | 8 hr avg. time | 15 μg/m^3^
NV | 8 hr avg. time | 36 μg/m^3^
TX | 30 min avg. time | 1.0 μg/m^3^
TX | 30 min. avg. time | 0.1 μg/m^3^
VA | 24 hr avg. time | 25 μg/m^3^
KY | Significant emission levels of toxic air pollutants | 3.827×10^−4^ pounds/hour | NREPC 1986 (KAR 401 63:022)
b. Other | Transportation of explosives is in accordance with the U.S. Department of Transportation hazardous materials regulations (49 CFR 171-190) and the motor carrier safety regulations (49 CFR 390-398) with some exceptions or additional requirements that vary from state to state. “Yes” in the Information column indicates that provisions for 49 CFR 171-170 and 49 CFR 390-398 exist in the specified state. | | CELDs 1991
AL | | Yes
AK | | Yes
AZ | | Yes
CA | | Yes
CT | | Yes
CO | | Yes
DE | | Yes
FL | | Yes
GA | | Yes
HI | | Yes
ID | | Yes
IN | | Yes
IA | | Yes
LA | | Yes
MD | | Yes
MA | | Yes
MI | | Yes
MN | | Yes
MS | | Yes
MO | | Yes
MT | | Yes
NE | | Yes
NJ | | Yes
NM | | Yes
NC | | Yes
ND | | Yes
NY | | Yes
OH | | Yes
OR | | Yes
RI | | Yes
SD | | Yes
TN | | Yes
TX | | Yes
UT | | Yes
VA | | Yes
VT | | Yes
WA | | Yes
WA-DC | | Yes
WV | | Yes
WI | | Yes
WY | | Yes
| Rules and regulations for air quality control and/or solid waste disposal have been established for explosives in general. The regulations vary from state to state. | | CELDs 1991
AL | Pretreatment standards for discharge | Yes
AL | Hazardous waste: Thermal treatment | Yes
AZ | Solid waste collection. | Yes
AR | Solid waste storage and collection | Yes
CO | Fugitive dust | Yes
CT | Hazardous waste: Thermal treatment | Yes
FL | Hazardous waste: Thermal treatment | Yes
GA | Open burning | Yes
IL | Sewer discharge | Yes
IN | Open burning | Yes
KY | Hazardous waste management | Yes
LA | Open burning | Yes
MN | Hazardous waste management | Yes
NH | Open burning | Yes
NJ | Hazardous waste management | Yes
NM | Hazardous waste management | Yes
NV | Hazardous waste management | Yes
NC | Hazardous waste: Thermal treatment | Yes
ND | Fugitive emissions | Yes
PA | Fugitive emissions | Yes
SC | Open burning | Yes
TN | Hazardous waste: Thermal treatment | Yes
UT | Hazardous waste management | Yes
VT | Open burning | Yes
VA | Solid waste management | Yes
WI | Open burning and malodorous emissions | Yes
WV | | none
WI | | none
| Explosive control laws regulate storage, manufacture, and use. The regulations vary from state to state. | | CELDs 1991
AK | | Yes
CA | | Yes
CT | | Yes
GA | | Yes
HI | | Yes
IN | | Yes
IA | | Yes
KS | | Yes
NJ | | Yes
MS | | Yes
NB | | Yes
NJ | | Yes
OK | | Yes
OR | | Yes
WA-DC | | Yes
WV | | Yes
WI | | Yes

NOTE: Units in table reflect values and units of measure designated by each agency in its regulations or advisories.

^a^Not classifiable as to human carcinogenicity.

ACGIH = American Conference of Governmental and Industrial Hygienists; CELDs = Comprehensive Environmental Legislative Database; CFR = Code of Federal Regulations; DOT = Department of Transportation; NATICH = National Air Toxics Information Clearinghouse; NIOSH = National Institute for Occupational Safety and Health; OSHA = Occupational Safety and Health Administration; PEL = Permissible exposure limit; REL = Recommended Exposure Limits; TLV = Threshold limit value; TWA = Time weighted average