# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Information regarding the chemical identity of tetryl is located in Table 3-1.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of tetryl is located in Table 3-2.

TABLE 3-1 Chemical Identity of Tetryl

Characteristic | Information | Reference
Chemical name | N-methyl-N,2,4,6-tetranitro-aniline | HSDB 1994
Synonym(s) | 2,4,6-trinitrophenyl-N-methylnitramine; N-methyl-N,2,4,6-tetranitrobenzenamine;N-picryl-N-methyl-nitramine;tetralit; tetralite; tetril;tetryl; trinitrophenyl-methylnitramine;nitramine; CE | HSDB 1994
Registered trade name(s) | No data
Chemical formula | C_7_H_5_N_5_O_8_ | HSDB 1994
Chemical structure | [image] | Merck 1989
Identification numbers:
CAS Registry | 479-45-8 | HSDB 1994
NIOSH RTECS | BY6300000 | HSDB 1994
EPA Hazardous Waste | No data
OHM/TADS | No data
DOT/UN/NA/IMCO | UN0208 | HSDB 1994
HSDB | 2857 | HSDB 1994
NCI | No data

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substance Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

TABLE 3-2 Physical and Chemical Properties of Tetryl

Property | Information | Reference
Molecular weight | 287.15 | Lide 1991
Color | Yellow | Sax and Lewis 1987
Physical state | Solid crystals | Sax and Lewis 1987
Melting point | 130–132 °C | Lide 1991
Melting point | 129.5 °C | Meyers 1987
Boiling point | 187 °C (explodes) | Lide 1991
Density at 19 °C | 1.57 | Lide 1991
Odor | Odorless | HSDB 1994
Odor threshold:
Water | No data
Air | No data
Solubility:
Fresh water at 20 °C | 75 mg/L | Army 1987d
Salt water at 25 °C | 26 mg/L | Hoffsommer and Rosen 1973; Merck 1989
Organic solvent(s) | Soluble in acetone, alcohol, ether, benzene, glacial acetic acid
Partition coefficients:
Log K_ow_ | 2.4^a^ | Army 1987d
Log K_oc_ | 3.13–3.47^b^ | Army 1987d
Vapor pressure at 20 °C | 4×10^−10^ torr^a^ | Army 1987d
Henry’s law constant:
at 25 °C | 2.0×10^−12^atm-m^3^/mol^a^ | Army 1987d
Autoignition temperature | No data
Flashpoint | Explodes | Mackison et al. 1978
Flammability limits at 25 °C | No data
Conversion factors at 25 °C | 1 ppm = 11.74 mg/m^3^ | HSDB 1994
Explosive limits | Explodes at 187 °C; impact sensitive | HSDB 1994

a Calculated values

b Estimated values

HSDB = Hazardous Substance Data Bank