# 9 REFERENCES

*Not cited in text

Abedin Z, Cook RC, Jr, Milberg RM. 1980. Cardiac toxicity of perchloroethylene (a dry cleaning agent). South Med J 73:1081–1083.7403923
Abrahamsson K, Ekdahl A, Cohen J, . 1995. Marine algae-a source of trichloroethylene and perchloroethylene. Limnol Oceanogr 40(7):1321–1326.
Abreu LDV, Johnson PC. 2005. Effect of vapor source-building separation and building construction on soil vapor intrusion as studied with a three-dimensional numerical model. Environ Sci Technol 39(12):4550–4561.16047792
ACGIH. 1991. Documentation of the threshold limit values and biological exposure indices. Sixth edition. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
ACGIH. 1995. Threshold limit values (TLVs) for chemical substances and physical agents and biological exposure indices (BEIs) for 1995-1996. Perchloroethylene. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
ACGIH. 2012. Tetrachloroethylene. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 55, 110.
Adgate JL, Church TR, Ryan AD, . 2004. Outdoor, indoor, and personal exposure to VOCs in children. Environ Health Perspect 112(14):1386–1392.15471730
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect 103(Suppl 7):103–112.
Aggazzotti G, Fantuzzi G, Predieri G, . 1994a. Indoor exposure to perchloroethylene (PCE) in individuals living with dry cleaning workers. Sci Total Environ 156:133–137.7992032
Aggazzotti G, Fantuzzi G, Righi E, . 1994b. Occupational and environmental exposure to perchloroethylene (PCE) in dry cleaners and their family members. Arch Environ Health 49(6):487–493.7818292
Ahlborg G Jr. 1990. Pregnancy outcome among women working in laundries and dry cleaning shops using tetrachloroethylene. Am J Ind Med 17:567–575.2337082
AIHA. 2011. Emergency response planning guidelines (ERPG). Fairfax, VA: American Industrial Hygiene Association. http://www.aiha.org/INSIDEAIHA/GUIDELINEDEVELOPMENT/ERPG/Pages/default.aspx. April 24, 2013.
Albee RR, Mattsson JL, Bradley GJ, . 1991. Acute neurophysiologic effects of 1,1,2,2-tetrachloroethylene in rats. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0540058. EPA88920003407.
Altman PL, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies of Experimental Biology.
Altmann L, Bottger A, Wiegand H. 1990. Neurophysiological and psychophysical measurements reveal effects of acute low-level organic solvent exposure in humans. Int Arch Occup Environ Health 62:493–499.2289821
Altmann L, Florian Neuhann H, Kramer U, . 1995. Neurobehavioral and neurophysiological outcome of chronic low-level tetrachloroethene exposure measured in neighborhoods of dry cleaning shops. Environ Res 69:83–89.8608774
Altmann L, Wiegand H, Bottger A, . 1992. Neurobehavioral and neurophysiological outcomes of acute repeated perchloroethylene exposure. Appl Psychol 41(3):269–279.
Anders MW, Lash L, Dekant W, . 1988. Biosynthesis and biotransformation of glutathione S-conjugates to toxic metabolites. CRC Crit Rev Toxicol 18:311–341.
Andersen A, Barlow L, Engeland A, . 1999. Work-related cancer in the Nordic countries. Scand J Work Environ Health 25(Suppl 2):1–116.
Andersen ME, Clewell HJ, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87(2):185–205.3824380
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, and replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Andrasik I, Cloutet D. 1990. Monitoring solvent vapors in dry cleaning plants. International Fabricare Institute Focus on Drycleaning 14(3):1–8.
Andrys C, Hanovcová I, Chỳlková V, . 1997. Immunological monitoring of dry-cleaning shop workers. Exposure to tetrachloroethylene. Cent Eur J Public Health 5(3):136–142.9386901
Anttila A, Pukkala E, Sallmen M, . 1995. Cancer incidence among Finnish workers exposed to halogenated hydrocarbons. J Occup Environ Med 37(7):797–806.7552463
Antoine SR, DeLeon IR, O’Dell-Smith RM. 1986. Environmentally significant volatile organic pollutants in human blood. Bull Environ Contam Toxicol 36:364–371.3955247
Aoki A, Suzaki H, Kawabata Y, . 1994. Effect of perchloroethylene inhalation on nasal mucosa in mice. Eur Arch Otorhinolaryngol 251:361–365.7848648
APHA. 1992. Standard methods for the examination of water and wastewater, 18th ed. American Public Health Association, American Water Works Association and Pollution Control Federation, Washington, DC, 6-42-6-47.
Aranda-Rodriguez R, Cabecinha A, Harvie J, . 2015. A method for quantification of volatile organic compounds in blood by SPME-GC-MS/MS with broader application: From non-occupational exposure population to exposure studies. J Chromatogr B Analyt Technol Biomed Life Sci 992:76–85. 10.1016/j.jchromb.2015.04.020.
Aranyi C, O’Shea WJ, Graham JA, . 1986. The effects of inhalation of organic chemical air contaminants on murine lung host defenses. Fundam Appl Toxicol 6:713–720.3519345
Aschengrau A, Ozonoff D, Paulu C, . 1993. Cancer risk and tetrachloroethylene-contaminated drinking water in Massachusetts. Arch Environ Health 48(5):284–292.8215591
Aschengrau A, Paulu C, Ozonoff D. 1998. Tetrachloroethylene-contaminated drinking water and the risk of breast cancer. Environ Health Perspect 106(Suppl 4):947–953.9703477
Aschengrau A, Rogers S, Ozonoff D. 2003. Perchloroethylene-contaminated drinking water and the risk of breast cancer: Additional results from Cape Cod, Massachusetts, USA. Environ Health Perspect 111(2):167–173.12573900
Aschengrau A, Weinberg JM, Janulewicz PA, . 2009. Prenatal exposure to tetrachloroethylene-contaminated drinking water and the risk of congenital anomalies: A retrospective cohort study. Environ Health 8:44.19778411
Aschengrau A, Weinberg JM, Janulewicz PA, . 2011. Affinity for risky behaviors following prenatal and early childhood exposure to tetrachloroethylene (PCE)-contaminated drinking water: A retrospective cohort study. Environ Health 10:102.22136431
Aschengrau A, Weinberg JM, Janulewicz PA, . 2012. Occurrence of mental illness following prenatal and early childhood exposure to tetrachloroethylene (PCE)-contaminated drinking water: A retrospective cohort study. Environ Health 11:2.22264316
Aschengrau A, Weinberg J, Rogers S, . 2008. Prenatal exposure to tetrachloroethylene-contaminated drinking water and the risk of adverse birth outcomes. Environ Health Perspect 116(6):814–820.18560539
Aschengrau A, Winter MR, Vieira VM, . 2015. Long-term health effects of early life exposure to tetrachloroethylene (PCE)-contaminated drinking water: A retrospective cohort study. Environ Health 14:36. 10.1186/s12940-015-0021-z.25889838
Ashley DL, Bonin MA, Cardinali FL, . 1992. Determining volatile organic compounds in human blood from a large sample population by using purge and trap gas chromatography/mass spectrometry. Anal Chem 64:1021–1029.1590585
Atkinson R. 1985. Kinetics and mechanisms of the gas-phase reactions of the hydroxyl radical with organic compounds under atmospheric conditions. Chem Rev 85:69–133.
Atkinson R, Carter WPL. 1984. Kinetics and mechanisms of the gas-phase reactions of ozone with organic compounds under atmospheric conditions. Chem Rev 84:437–470.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
ATSDR. 1997. Toxicological profile for trichloroethylene. U.S. Department of Health and Human Services, Agency for Toxic Substances and Disease Registry, TP-92/18.
ATSDR. 1998. Volatile organic compounds in drinking water and adverse pregnancy outcome. United State Marine Corps Base, Camp Lejeune, North Carolina. U.S. Department of Health and Human Services, Public Health Service.
ATSDR. 2004. Interaction profile for 1,1,1-trichloroethane, 1,1-dichloroethane, trichloroethylene and tetrachloroethylene. Atlanta, GA: U.S. Department of Health and Human Services, Agency for Toxic Substances and Disease Registry.
ATSDR. 2006a. Health consultation. Evaluation of tetrachloroethylene vapor intrusion into buildings located above a contaminated aquifer. Atlanta, GA: U.S. Department of Health and Human Services, Agency for Toxic Substances and Disease Registry, Division of Health Assessment and Consultation.
ATSDR. 2006b. Toxicological profile for vinyl chloride. Atlanta, GA: Agency for Toxic Substances and Disease Registry, U.S. Department of Health and Human Services.
ATSDR. 2007a. Analyses of groundwater flow, contaminant fate and transport, and distribution of drinking water at Tarawa terrace and vicinity, U.S. Marine Corps Base Camp Lejeune, North Carolina: Historical reconstruction and present-day conditions. Chapter E: Occurrence of contaminants in groundwater. Atlanta, GA: U.S. Department of Health and Human Services, Agency for Toxic Substances and Disease Registry, Division of Health Assessment and Consultation. http://www.atsdr.cdc.gov/sites/lejeune/docs/ChapterE_TarawaTerrace_revised0108.pdf. August 27, 2013.
ATSDR. 2007b. Interaction profile for carbon monoxide, formaldehyde, methylene chloride, nitrogen dioxide, and tetrachloroethylene. Atlanta, GA: U.S. Department of Health and Human Services, Agency for Toxic Substances and Disease Registry.
ATSDR. 2013. Volatile organic compounds in drinking water. Camp Lejeune. Atlanta, GA: Centers for Disease Control and Prevention, Agency for Toxic Substances and Disease Registry.
ATSDR. 2014. Medical Management Guidelines (MMGs). Tetrachloroethylene. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/mmg/mmg.asp?id=261&tid=48.pdf. September 3, 2018.
ATSDR. 2016. Addendum to the toxicological profile for vinyl chloride. Atlanta, GA: Agency for Toxic Substances and Disease Registry, U.S. Department of Health and Human Services.
ATSDR. 2017a. Tetrachloroethylene. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention. http://www.atsdr.cdc.gov/SPL/resources/index.html. May 29, 2018.
ATSDR. 2017b. ATSDR Assessment of the evidence for the drinking water contaminants at Camp Lejeune and specific cancers and other diseases. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/sites/lejeune/docs/atsdr_summary_of_the_evidence_for_causality_tce_pce_508.pdf. October 22, 2018.
ATSDR. 2018. Agency for Toxic Substances and Disease Registry case studies in environmental medicine. Tetrachloroethylene toxicity. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/csem/csem.asp?csem=36&po=0.pdf. September 3, 2018.
Azimi M, Bahrami MR, Rezaei Hachesu V, . 2017. Primary DNA damage in dry cleaners with perchlorethylene exposure. Int J Occup Environ Med 8(4):224–231. 10.15171/ijoem.2017.1089.28970597
Bagnell PC, Ellenberger HA. 1977. Obstructive jaundice due to a chlorinated hydrocarbon in breast milk. Can Med Assoc J 117:1047–1048.912629
Bale AS, Barone S, Scott CS, . 2011. A review of potential neurotoxic mechanisms among three chlorinated organic solvents. Toxicol Appl Pharmacol 255(1):113–126.21609728
Bale AS, Meacham CA, Benignus VA, . 2005. Volatile organic compounds inhibit human and rat neuronal nicotinic acetylcholine receptors expressed in Xenopus oocytes. Toxicol Appl Pharmacol 205(1):77–88.15885267
Barber LB II, Thurman EM, Schroeder MP. 1988. Long-term fate of organic micropollutants in sewage-contaminated groundwater. Environ Sci Technol 22:205–211.19995023
Barkley J, Bunch J, Bursey JT, . 1980. Gas chromatography/mass spectrometry computer analysis of volatile halogenated hydrocarbons in man and his environment. A multimedia environmental study. Biomed Mass Spectrom 7:139–147.7448328
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Barrows ME, Petrocelli SR, Macek KJ, . 1980. Bioconcentration and elimination of selected water pollutants by bluegill sunfish (Lepomis macrochirus). In: Haque R, ed. Dynamics, exposure and hazard assessment of toxic chemicals. Ann Arbor, MI: Ann Arbor Science, 379–392.
Bartels MJ. 1994. Quantitation of the tetrachloroethylene metabolite N-acetyl-S-(trichlorovinyl) cysteine in rat urine via negative ion chemical ionization gas chromatography/tandem mass spectrometry. Biol Mass Spectrom 23:689–694.7811758
Bartsch H, Malaveille C, Barbin A, . 1979. Mutagenic and alkylating metabolites of haloethylenes, chlorobutadienes, and dichlorobutenes produced by rodent or human liver tissues. Arch Toxicol 41:249–277.373707
Bayer CW, Black MS. 1987. Capillary chromatographic analysis of volatile organic compounds in the indoor environment. J Chromatogr Sci 25(2):60–64.3558698
Baykut G, Voigt A. 1992. Spray extraction of volatile organic compounds from aqueous systems into the gas phase for gas chromatography/mass spectrometry. Anal Chem 64:677–681.
Begerow J, Jermann E, Keles T, . 1996. Screening method for the determination of 28 volatile organic compounds in indoor and outdoor air at environmental concentrations using dual-column capillary gas chromatography with tandem electron-capture-flame ionization detection. J Chromatogr A 749(1–2):181–191.
Benane SG, Blackman CF, House DE. 1996. Effect of perchloroethylene and its metabolites on intercellular communication in clone 9 rat liver cells. J Toxicol Environ Health 48(5):427–437.8751833
Benfenati E, Facchini G, Pierucci P, . 1996. Identification of organic contaminants in leachates from industrial waste landfills. Trends Anal Chem 15(8):305–310.
Benignus VA, Boyes WK, Geller AM, . 2009. Long-term perchloroethylene exposure: A meta-analysis of neurobehavioral deficits in occupationally and residentially exposed groups. J Toxicol Environ Health A 72(13):824–831.19557610
Bentley P, Calder I, Elcombe C, . 1993. Hepatic peroxisome proliferation in rodents and its significance for humans. Food Chem Toxicol 31(11):857–907.8258416
Bergamaschi E, Mutti A, Bocchi MC, . 1992. Rat model of perchloroethylene-induced renal dysfunctions. Environ Res 59:427–439.1281447
Berger GS, ed. 1994. Epidemiology of endometriosis. In: Endometriosis: Modern surgical management of endometriosis. New York, NY: Springer-Verlag, 3–7.
Berger T, Horner CM. 2003. In vivo exposure of female rats to toxicants may affect oocyte quality. Reprod Toxicol 17(3):273–281.12759095
Berman E, Schlicht M, Moser VC, . 1995. A multidisciplinary approach to toxicological screening: I. Systemic toxicity. J Toxicol Environ Health 45:127–143.7783250
*Birner G, Richling C, Henschler D, . 1994. Metabolism of tetrachloroethylene in rats: Identification of N-(dichloroacetyl)-L-lysine and N-(trichloroacetyl)-L-lysine as protein adducts. Chem Res Toxicol 7:724–732.7696525
Birner G, Rutkowska A, Dekant W. 1996. N-Acetyl-S-(1,2,2-trichlorovinyl)-L-cysteine and 2,2,2-trichloroethanol: Two novel metabolites of tetrachloroethene in humans after occupational exposure. Drug Metab Dispos 24(1):41–48.8825189
Blair A, Decoufle P, Grauman D. 1979. Causes of death among laundry and dry cleaning workers. Am J Public Health 69:508–511.434285
Blair A, Petralia SA, Stewart PA. 2003. Extended mortality follow-up of a cohort of dry-cleaners. Ann Epidemiol 13(1):50–56.12547485
Blair A, Stewart PA, Tolbert PE, . 1990. Cancer and other causes of death among a cohort of dry cleaners. Br J Ind Med 47:162–168.2328223
Blount BC, Kobelski RJ, McElprang DO, . 2006. Quantification of 31 volatile organic compounds in whole blood using solid-phase microextraction and gas chromatography-mass spectrometry. J Chromatogr B 832(2):292–301.
Boekhold AJ, Van Der Schee HA, Kaandorp BH. 1989. [Rapid gas-chromatographic determination of trichloroethylene and/or tetrachloroethylene in lettuce by direct head-space analysis]. Z Lebensm Unters Forsch 189:550–553. (German)2609777
Bogen KT, Colston BW Jr., Machicao LK. 1992. Dermal absorption of diluted aqueous chloroform, trichloroethylene, and tetrachloroethylene in hairless guinea pigs. Fundam Appl Toxicol 18:30–39.1601207
Boice JD, Jr., Marano DE, Fryzek JP, . 1999. Mortality among aircraft manufacturing workers. Occup Environ Med 56(9):581–597.10615290
Bois FY, Zeise L, Tozer TN. 1990. Precision and sensitivity of pharmacokinetic models for cancer risk assessments: Tetrachloroethylene in mice, rats, and humans. Toxicol Appl Pharmacol 102:300–315.2300971
Bosco MG, Figa-Talamanca I, Salerno S. 1986. Health and reproductive status of female workers in dry cleaning shops. Int Arch Occup Environ Health 59:295–301.
Bouwer EJ, McCarty PL. 1982. Removal of trace chlorinated organic compounds by activated carbon and fixed-film bacteria. Environ Sci Technol 16:836–843.22236258
Bouwer EJ, Rittmann BE, McCarty PL. 1981. Anaerobic degradation of halogenated 1- and 2-carbon organic compounds. Environ Sci Technol 15:596–599.22283955
Bove FJ, Fulcomer MC, Klotz JB. 1995. Public drinking water contamination and birth outcomes. Am J Epidemiol 141:850–862.7717362
Bove FJ, Ruckart PZ, Maslia M, . 2014a. Evaluation of mortality among marines and navy personnel exposed to contaminated drinking water at USMC Base Camp Lejeune: A retrospective cohort study. Environ Health 13(1):10. 10.1186/1476-069X-13-10.24552493
Bove FJ, Ruckart PZ, Maslia M, . 2014b. Mortality study of civilian employees exposed to contaminated drinking water at USMC Base Camp Lejeune: A retrospective cohort study. Environ Health 13:68. 10.1186/1476-069x-13-68.
Boverhof DR, Krieger SM, Hotchkiss JA, . 2013. Assessment of the immunotoxic potential of trichloroethylene and perchloroethylene in rats following inhalation exposure. J Immunotoxicol 10(3):311–320.23167264
Boyes WK, Bercegeay M, Oshiro WM, . 2009. Acute perchloroethylene exposure alters rat visual-evoked potentials in relation to brain concentrations. Toxicol Sci 108(1):159–172.19098276
Briving C, Jacobson I, Hamberger A, . 1986. Chronic effects of perchloroethylene and trichloroethylene on the gerbil brain amino acids and glutathione. Neurotoxicology 7:101–108.2872637
Brodkin CA, Daniell W, Checkoway H, . 1995. Hepatic ultrasonic changes in workers exposed to perchloroethylene. Occup Environ Med 52:679–685.7489059
*Bronstein AC, Currance PL. 1988. Flammable liquids. In: Emergency care for hazardous materials exposure. Washington, DC: The C.V. Mosby Company, 93–94.
Bronzetti G, Bauer C, Corsi R, . 1983. Genetic and biochemical studies on perchloroethylene in vitro and in vivo. Mutat Res 116:323–331.6339899
*Brouwer M, Koeman T, van den Brandt PA, . 2015. Occupational exposures and Parkinson’s disease mortality in a prospective Dutch cohort. Occup Environ Med 72(6):448–455. 10.1136/oemed-2014-102209.25713156
Brown DP, Kaplan SD. 1987. Retrospective cohort mortality study of dry cleaning workers using perchloroethylene. J Occup Med 29:535–541.3612328
Brown RP, Delp MD, Lindstedt SL, . 1997. Physiologically parameter values for physiologically based pharmacokinetic models. Toxicol Ind Health 13(4):407–484.9249929
Brugnone F, Perbellini L, Giuliari C, . 1994. Blood and urine concentrations of chemical pollutants in the general population. Med Lav 85(5):370–389.7885292
Buben JA, O’Flaherty EJ. 1985. Delineation of the role of metabolism in the hepatotoxicity of trichloroethylene and perchloroethylene: A dose-effect study. Toxicol Appl Pharmacol 78:105–122.2994252
Budavari S, ed. 1989. Tetrachloroethylene. In: The Merck index. 11th ed. Rahway, NJ: Merck and Co., Inc., 1449.
Bukowski J. 2014. Critical review of the epidemiologic literature regarding the association between congenital heart defects and exposure to trichloroethylene. Crit Rev Toxicol 44(7):581–589. 10.3109/10408444.2014.910755.24898789
Bundschuh I, Herbort C, Fels LM, . 1993. Renal fibronectin excretion as a marker for renal environmental toxins. Contrib Nephrol 101:177–184.8467673
Burk T, Zarus G. 2013. Community exposures to chemicals through vapor intrusion: A review of past Agency for Toxic Substances and Disease Registry public health evaluations. J Environ Health 75(9):36–41.
Byczkowski JZ, Fisher JW. 1994. Lactational transfer of tetrachloroethylene in rats. Risk Anal 14(3):339–349.8029506
Byczkowski JZ, Fisher JW. 1995. A computer program linking physiologically based pharmacokinetic model with cancer risk assessment for breast-fed infants. Comput Methods Programs Biomed 46:155–163.7796584
Byczkowski JZ, Kinkead ER, Leahy HF, . 1994. Computer simulation of the lactational transfer of tetrachloroethylene in rats using a physiologically based model. Toxicol Appl Pharmacol 125:228–236.8171430
Byers VS, Levin AS, Ozonoff DM, . 1988. Association between clinical symptoms and lymphocyte abnormalities in a population with chronic domestic exposure to industrial solvent-contaminated domestic water supply and a high incidence of leukemia. Cancer Immunol Immunother 27:77–81.3260823
Cabirol N, Jacob F, Perrier J, . 1998. Complete degradation of high concentrations of tetrachloroethylene by a methanogenic consortium in a fixed-bed reactor. J Biotechnol 62(2):133–141.
Cabirol N, Perrier J, Jacob F, . 1996. Role of methanogenic and sulfate-reducing bacteria in the reductive dechlorination of tetrachloroethylene in mixed culture. Bull Environ Contam Toxicol 56(5):817–824.8661867
Cai S-X, Huang M-Y, Chen Z, . 1991. Subjective symptom increase among dry cleaning workers exposed to tetrachloroethylene vapor. Ind Health 29:111–121.1765547
Cal EPA. 1999. Public health goal for trichloroethylene in drinking water. California Environmental Protection Agency, Office of Environmental Health Hazard Assessment.
Cal EPA. 2001. Public health goal for tetrachloroethylene in drinking water. California Environmental Protection Agency, Office of Environmental Health Hazard Assessment.
Callen DF, Wolf CR, Philpot RM. 1980. Cytochrome P-450 mediated genetic activity and cytotoxicity of seven halogenated aliphatic hydrocarbons in Saccharomyces cerevisiae. Mutat Res 77:55–63.6767185
Calvert GM, Ruder AM, Petersen MR. 2011. Mortality and end-stage renal disease incidence among dry cleaning workers. Occup Environ Med 68(10):709–716.21172794
*Cano MI, Pollan M. 2001. Non-Hodgkin’s lymphomas and occupation in Sweden. Int Arch Occup Environ Health 74(6):443–449.11563608
Carney EW, Thorsrud BA, Dugard PH, . 2006. Developmental toxicity studies in Crl:CD (SD) rats following inhalation exposure to trichloroethylene and perchloroethylene. Birth Defects Res B Dev Reprod Toxicol 77(5):405–412.17066414
Carpenter CP. 1937. The chronic toxicity of tetrachloroethylene. J Ind Hyg Toxicol 19:323–336.
Carwile JL, Mahalingaiah S, Winter MR, . 2014. Prenatal drinking-water exposure to tetrachloroethylene and ischemic placental disease: A retrospective cohort study. Environ Health 13:72. 10.1186/1476-069x-13-72.25270247
Cavalleri A, Gobba F. 1998. Reversible color vision loss in occupational exposure to metallic mercury. Environ Res 77:173–177.9600811
Cavalleri A, Gobba F, Paltrinieri M, . 1994. Perchloroethylene exposure can induce colour vision loss. Neurosci Lett 179:162–166.7845613
CDC. 2015. Fourth national report on human exposure to environmental chemicals, updated tables (February 2015). Centers for Disease Control and Prevention. http://www.cdc.gov/biomonitoring/pdf/FourthReport_UpdatedTables_Feb2015.pdf. December 14, 2015.
CDPHE. 2002. Fact sheet. Dry cleaners and PCE. Colorado Department of Public Health and Environment.
CDPHE. 2006. Dry cleaner remediation guidance document. Colorado Department of Public Health and Environment.
Cederberg H, Henriksson J, Binderup ML. 2010. DNA damage detected by the alkaline comet assay in the liver of mice after oral administration of tetrachloroethylene. Mutagenesis 25(2):133–138.19892777
CEPA. 1993. Canadian Environmental Protection Act. Priority substances list assessment report: Tetrachloroethylene. Government of Canada, Environment Canada, Health Canada, 10–14, 29–30.
CEPA. 2001. Public health goal for tetrachloroethylene in drinking water. California Environmental Protection Agency, Office of Environmental Health Hazard Assessment.
Chai JC, Miura N. 2004. Field vapor extraction test and long-term monitoring at a PCE contaminated site. J Hazard Mater 110:85–92.15177729
Chang YC, Hatsu M, Jung K, . 1998. Degradation of a variety of halogenated aliphatic compounds by an anaerobic mixed culture. J Ferment Bioengineer 86(4):410–412.
Chang YC, Ikeutsu K, Toyama T, . 2011. Isolation and characterization of tetrachloroethylene- and cis-1,2-dichloroethylene-dechlorinating propionibacteria. J Ind Microbiol Biotechnol 38(10):1667–1677.21437617
Chang YM, Tai CF, Yang SC, . 2003. A cohort mortality study of workers exposed to chlorinated organic solvents in Taiwan. Ann Epidemiol 13(9):652–660.14732305
*Chang YM, Tai CF, Yang SC, . 2005. Cancer incidence among workers potentially exposed to chlorinated solvents in an electronics factory. J Occup Health 47(2):171–180.15824483
Chapman JAW, Connolly JG, Rosenbaum L. 1981. Occupational bladder cancer: A case-control study. In: Connoly JE, ed. Carcinoma of the bladder. New York, NY: Raven Press, 45–54.
Charbotel B, Massardier-Pilonchery A, Fort E, . 2013. Occupational trichloroethylene exposure and cervical pathology: A case-control study. Ann Occup Hyg 57(3):407–416. 10.1093/annhyg/mes075.23091111
Chaudhuri RN, Mukerji AK. 1947. Death following administration of tetrachloroethylene. Ind Med Gaz 82:115–116.
C&EN. 1994. Facts and figures for the chemical industry. Chemical and Engineering News, July 4, 1994.
Chemical Products Synopsis. 1985. Perchloroethylene. Mannsville Chemical Products Corp., Cortland, NY.
Chemical Profile. 1995. Perchloroethylene. Chemical Marketing Reporter, March 13, 1995.
Chen CW, Blancato JN. 1987. Role of pharmacokinetic modeling in risk assessment: Perchloroethylene as an example. In: Pharmacokinetics in risk assessment, drinking water and health. Vol. 8. Washington, DC: National Academy of Sciences, National Research Council, 369–390.
Chen KM, Dallas CE, Muralidhara S, . 1993. Analyses of volatile C_2_ haloethanes and haloethenes in tissues: Sample preparation and extraction. J Chromatogr 612:199–208.8468377
Chen SJ, Wang JL, Chen JH, . 2002. Possible involvement of glutathione and p53 in trichloroethylene- and perchloroethylene-induced lipid peroxidation and apoptosis in human lung cancer cells. Free Radic Biol Med 33(4):464–472.12160929
Chiappini L, Delery L, Leoz E, . 2009. A first French assessment of population exposure to tetrachloroethylene from small dry-cleaning facilities. Indoor Air 19:226–233.19298226
Chilton PJ, Lawrence AR, Barker A. 1990. Chlorinated solvents in chalk aquifers: Some preliminary observations on behavior and transport. In: Telford T, ed. International Chalk Symposium. London, England, 605–610.
Chiu WA, Ginsberg GL. 2011. Development and evaluation of a harmonized physiologically based pharmacokinetic (PBPK) model for perchloroethylene toxicokinetics in mice, rats, and humans. Toxicol Appl Pharmacol 253(3):203–234.21466818
Chiu WA, Micallef S, Monster AC, . 2007. Toxicokinetics of inhaled trichloroethylene and tetrachloroethylene in humans at 1 ppm: Empirical results and comparisons with previous studies. Toxicol Sci 95(1):23–36.17032701
Chiu WA, Okino MS, Evans MV. 2009. Characterizing uncertainty and population variability in the toxicokinetics of trichloroethylene and metabolites in mice, rats, and humans using an updated database, physiologically based pharmacokinetic (PBPK) model, and Bayesian approach. Toxicol Appl Pharmacol 241:36–60.19660485
Chodola GR, Biswas N, Bewtra JK, . 1989. Fate of selected volatile organic substances in aqueous environment. Water Pollut Res J Can 24:119–142.
Christensen JM, Rasmussen K, Koppen B. 1988. Automatic headspace gas chromatographic method for the simultaneous determination of trichloroethylene and metabolites in blood and urine. J Chromatogr 442:317–323.3417822
Christensen KY, Vizcaya D, Richardson H, . 2013. Risk of selected cancers due to occupational exposure to chlorinated solvents in a case-control study in Montreal. J Occup Environ Med 55(2):198–208. 10.1097/JOM.0b013e3182728eab.23147555
Cichocka D, Nikolausz M, Haest PJ, . 2010. Tetrachloroethene conversion to ethene by a dehalococcoides-containing enrichment culture from Bitterfeld. FEMS Microbiol Ecol 72(2):297–310.20507364
Cichocki JA, Furuya S, Konganti K, . 2017a. Impact of nonalcoholic fatty liver disease on toxicokinetics of tetrachloroethylene in mice. J Pharmacol Exp Ther 361(1):17–28. 10.1124/jpet.116.238790.28148637
Cichocki JA, Furuya S, Luo YS, . 2017b. Nonalcoholic fatty liver disease is a susceptibility factor for perchloroethylene-induced liver effects in mice. Toxicol Sci 159(1):102–113. 10.1093/toxsci/kfx120.28903486
Cichocki JA, Furuya S, Venkatratnam A, . 2017c. Characterization of variability in toxicokinetics and toxicodynamics of tetrachloroethylene using the collaborative cross mouse population. Environ Health Perspect 125(5):057006. 10.1289/ehp788.28572074
Cichocki JA, Guyton KZ, Guha N, . 2016. Target organ metabolism, toxicity, and mechanisms of trichloroethylene and perchloroethylene: Key similarities, differences, and data gaps. J Pharmacol Exp Ther 359(1):110–123. 10.1124/jpet.116.232629.27511820
Class TH, Ballschmiter K. 1986. Chemistry of organic traces in air. VI: Distribution of chlorinated C1-C4 hydrocarbons in air over the northern and southern Atlantic Ocean. Chemosphere 15:413–427.
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Clewell HJ, Gentry PR, Covington TR, . 2004. Evaluation of the potential impact of age- and gender-specific pharmacokinetic differences on tissue dosimetry. Toxicol Sci 79(2):381–393.15056818
CMR. 2008. Chemical profile: Perchloroethylene. Chemical Marketing Reporter. http://www.icis.com/Articles/2008/08/25/9150899/chemical-profile-perchloroethylene.html. March 11, 2013.
Cohn P, J Klotz, F Bove, . 1994. Drinking water contamination and the incidence of leukemia and non-Hodgkin’s lymphoma. Environ Health Perspect 102(6–7):556–561.9679115
Coler HR, Rossmiller HR. 1953. Tetrachloroethylene exposure in a small industry. AMA Arch Ind Hyg Occup Med 8:227–233.13079324
*Corbin M, McLean D, Mannetje A, . 2011. Lung cancer and occupation: A New Zealand cancer registry-based case-control study. Am J Ind Med 54(2):89–101. 10.1002/ajim.20906.20957667
Cornish HH, Adefuin J. 1966. Ethanol potentiation of halogenated aliphatic solvent toxicity. Am Ind Hyg Assoc J 27:57–61.5920489
Cornish HH, Ling BP, Barth ML. 1973. Phenobarbital and organic solvent toxicity. Am Ind Hyg Assoc J 34:487–492.4770171
Costa AK, Ivanetich KM. 1980. Tetrachloroethylene metabolism by the hepatic microsomal cytochrome P-450 system. Biochem Pharmacol 29:2863–2869.7437086
Costa LG, Aschner M, Vitalone A, . 2004. Developmental neuropathology of environmental agents. Ann Rev Pharmacol Toxicol 44:87–110. 10.1146/annurev.pharmtox.44.101802.121424.
Cramer PH, Boggess KE, Hosenfeld JM, . 1988. Determination of organic chemicals in human whole blood: Preliminary method development for volatile organics. Bull Environ Contam Toxicol 40(4):612–618.3370355
Cupitt LT. 1987. Atmospheric persistence of eight air toxics. Environmental Protection Agency, Research Triangle Park, NC, Atmospheric Sciences Research Lab. EPA600S387004.
Daft JL. 1988. Rapid determination of fumigant and industrial chemical residues in food. J Assoc Off Anal Chem 71:748–760.3417594
Daft JL. 1989. Determination of fumigants and related chemicals in fatty and nonfatty foods. J Agric Food Chem 37:560–564.
*Dallas CE, Chen XM, Muralidhara S, . 1994a. Use of tissue disposition data from rats and dogs to determine species differences in input parameters for physiological model for perchloroethylene. Environ Res 67:54–67.7925194
Dallas CE, Chen XM, Muralidhara S, . 1995. Physiologically based pharmacokinetic model useful in prediction of the influence of species, dose, and exposure route on perchloroethylene pharmacokinetics. J Toxicol Environ Health 44:301–317.7897693
Dallas CE, Chen XM, O’Barr K, . 1994b. Development of a physiologically based pharmacokinetic model for perchloroethylene using tissue concentration - time data. Toxicol Appl Pharmacol 128:50–59.8079354
Dallas CE, Muralidhara S, Chen XM, . 1994c. Use of a physiologically based model to predict systemic uptake and respiratory elimination of perchloroethylene. Toxicol Appl Pharmacol 128:60–68.8079355
*Daniel JW. 1963. The metabolism of ^36^Cl-labeled trichloroethylene and tetrachloroethylene in the rat. Biochem Pharmacol 12:795–802.14071536
*Dart RC. 2004. Halogenated hydrocarbons-halogenated solvents. In: Medical toxicology. 3^rd^ ed. Philadelphia, PA: Lippincott Williams and Wilkins, 1339–1341.
Dawson HE, McAlary T. 2009. A compilation of statistics for VOCs from post-1990 indoor air concentration studies in North American residences unaffected by subsurface vapor intrusion. Ground Water Monit Remed 29(1):60–69.
De Ceaurriz J, Desiles JP, Bonnet P, . 1983. Concentration-dependent behavioral changes in mice following short-term inhalation exposure to various industrial solvents. Toxicol Appl Pharmacol 67:383–389.6845368
Dehon B, Humbert L, Devisme L, . 2000. Tetrachloroethylene and trichloroethylene fatality: Case report and simple headspace SPME-capillary gas chromatographic determination in tissues. J Anal Toxicol 24(1):22–26.10654565
Deipser A, Stegmann, R. 1994. The origin and fate of volatile trace components in municipal solid waste landfills. Waste Manag Res 12:129–139.
Dekant W. 1986. Metabolic conversion of tri- and tetrachloroethylene: Formation and deactivation of genotoxic intermediates. In: Chambers PL, Gehring P, Sakai F, eds. New concepts and developments in toxicology. Elsevier Science Publishers 211–221.
Dekant W, Martens G, Vamavakas S, . 1987. Bioactivation of tetrachloroethylene. Role of glutathione s-transferase-catalyzed conjugation versus cytochrome P-450 dependent phospholipid alkylation. Drug Metab Dispos 15:702–709.2891489
Dekant W, Metzler M, Henschler D. 1986. Identification of S-1,2,2-trichlorovinyl-n-acetylcysteine as a urinary metabolite of tetrachloroethylene: Bioactivation through glutathione conjugation as a possible explanation of its nephrocarcinogenicity. J Biochem Toxicol 1:57–72.3271876
Delfino RJ, Gong HH, Linn WS, . 2003. Respiratory symptoms and peak expiratory flow in children with asthma in relation to volatile organic compounds in exhaled breath and ambient air. J Expo Anal Environ Epidemiol 13:348–363.12973363
De Raat K. 2003. The Nordic Expert Group for criteria documentation of health risks from chemicals and the Dutch Expert Committee on occupational standards. Tetrachloroethylene (PER). Stockholm, Sweden: Nordic Council of Ministers.
DeWulf J, Van Langehove H, Heireman B. 1998. The air/water exchange of volatile organic compounds from waters in the transient and turbulent regime. Water Res 32(7):2106–2112.
DHHS. 1994. Seventh annual report on carcinogens. Summary 1994. U.S. Department of Health and Human Services, Public Health Service. Report to the National Institute of Environmental Health Sciences, Research Triangle Park, NC, by Technical Resources, Inc., Rockville, MD, 372–376.
Diamadopoulos DS, Koukouraki E. 1998. The effect of humic acid on the transport of volatile chlorinated hydrocarbons in soil. Water Res 32(11):3325–3330.
Dias CM, Menezes HC, Cardeal ZL. 2017. Use of exhaled air as an improved biomonitoring method to assess perchloroethylene short-term exposure. Environ Res 156:108–112.28342345
Dickson AG, Riley JP. 1976. The distribution of short-chain halogenated aliphatic hydrocarbons in some marine organisms. Mar Pollut Bull 7:167–169.
Dietz EA, Singley KF. 1979. Determination of chlorinated hydrocarbons in water by headspace gas chromatography. Anal Chem 51(11):1809–1814.
Dilling WL. 1977. Interphase transfer processes. II. Evaporation rates of chloromethanes, ethanes, ethylenes, propanes, and propylenes from dilute aqueous solutions. Comparisons with theoretical predictions. Environ Sci Technol 11:405–409.
Dilling WL, Tefertiller NB, Kallos GJ. 1975. Evaporation rates and reactivities of methylene chloride, chloroform, 1,1,1-trichloroethane, trichloroethylene, tetrachloroethylene, and other chlorinated compounds in dilute aqueous solutions. Environ Sci Technol 9:833–838.
DiStefano TD, Gossett JM, Zinder SH. 1991. Reductive dechlorination of high concentrations of tetrachloroethene to ethene by an anaerobic enrichment culture in the absence of methanogenesis. Appl Environ Microbiol 57(8):2287–2292.1768101
DOE. 2012. Protective action criteria (PAC). Oak Ridge, TN: U.S. Department of Energy and Subcommittee on Consequence Assessment and Protective Actions (SCAPA). http://orise.orau.gov/emi/scapa/chem-pacs-teels/default.htm. April 24, 2013.
Dosemeci M, Cocco P, Chow WH. 1999. Gender differences in risk of renal cell carcinoma and occupational exposures to chlorinated aliphatic hydrocarbons. Am J Ind Med 36:54–59.10361587
Doust HG, Huang J. 1992. The fate and transport of hazardous chemicals in the subsurface environment. Water Sci Technol 25:169–176.
Dow. 2008. Product safety assessment perchloroethylene. Dow Chemical Company.
*Dow Chemical. 1983. Initial submission: Perchloroethylene solvent formulation: Acute toxicological properties and industrial handling hazards. Submitted to the U.S. Environmental Protection Agency under TSCA, Section 8e. OTS0574294.
Doyle P, Roman E, Beral V, . 1997. Spontaneous abortion in dry cleaning workers potentially exposed to perchloroethylene. Occup Environ Med 54(12):848–853.9470891
Duh RW, Asal NR. 1984. Mortality among laundry and dry cleaning workers in Oklahoma. Am J Public Health 74:1278–1280.6496825
Dyksen JE, Hess AF III. 1982. Alternatives for controlling organics in groundwater supplies. J Am Water Works Assoc 74:394–402.
Earnest GS. 1995. In-depth survey report: Chemical exposures and fire safety in commercial dry cleaners at A-One Cleaners, Cincinnati, Ohio. U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control and Prevention, National Institute for Occupational Safety and Health. Report No. ECTB 201-18a.
Earnest GS. 1996. Evaluation and control of perchloroethylene exposure during dry cleaning. Appl Occup Environ Hyg 11(2):125–132.
Earnest GS, Spencer AB. 1995. In-depth survey report: Perchloroethylene exposures in commercial dry cleaners at Brown’s Cleaners, Santa Monica, California. U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control and Prevention, National Institute for Occupational Safety and Health. Report No. ECTB 201-16a.
Earnest GS, Moran AJ, Spencer AB, . 1995a. In-depth survey report: Control of perchloroethylene exposures in commercial dry cleaners at Appearance Plus Cleaners, Cincinnati, Ohio. U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control and Prevention, National Institute for Occupational Safety and Health. Report No. ECTB: 201-15a.
Earnest GS, Moran AJ, Spencer AB. 1995b. In-depth survey report: Perchloroethylene exposures in commercial dry cleaners at Tuchman Cleaners (shop #27), Fishers, Indiana. U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control and Prevention, National Institute for Occupational Safety and Health. Report No. ECTB: 201-17a.
Earnest GS, Spencer AB, Smith SS, . 1995c. In-depth survey report: Perchloroethylene exposures and ergonomic risk factors in commercial dry cleaners at Tuchman Cleaners (shop #24), Carmel, Indiana. U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control and Prevention, National Institute for Occupational Safety and Health. Report No. ECTB: 201-19a.
Ebrahim AS, Babakrishnan K, Sakthisekaran D. 1996. Perchloroethylene-induced alterations in glucose metabolism and their prevention by 2-deoxy-D-glucose and vitamin E in mice. J Appl Toxicol 16(4):339–348.8854221
Ebrahim AS, Babu E, Thirunavukkarasu C, . 2001. Protective role of vitamin E, 2-deoxy-D-glucose, and taurine on perchloroethylene induced alterations in ATPases. Drug Chem Toxicol 24(4):429–437.11665651
Ebrahim AS, Gopalakrishnan R, Murugesan A, . 1995. In vivo effect of vitamin E on serum and tissue glycoprotein levels in perchloroethylene induced cytotoxicity. Mol Cell Biol 144:13–18.
Echeverria D, White RF, Sampaio C. 1995. A behavioral evaluation of PCE exposure in patients and dry cleaners: A possible relationship between clinical and preclinical effects. J Occup Environ Med 37(6):667–680.7670913
E.I. Dupont. 1969. Cardiac sensitization in dogs. Submitted to the U.S. Environmental Protection Agency under TSCA, Section 8d. OTS0514917.
Ek CJ, Dziegielewska KM, Habgood MD, . 2012. Barriers in the developing brain and neurotoxicology. Neurotoxicology 33(3):586–604. 10.1016/j.neuro.2011.12.009.22198708
*Ellenhorn MJ, Barceloux DG. 1988. Airborne toxins. In: Medical toxicology: Diagnosis and treatment of human poisoning. New York, NY: Elsevier, 841–843.
Emara AM, Abo El-Noor MM, Hassan NA, . 2010. Immunotoxicity and hematotoxicity induced by tetrachloroethylene in Egyptian dry cleaning workers. Inhal Toxicol 22(2):117–124.
Emmert B, Bunger J, Keuch K, . 2006. Mutagenicity of cytochrome P450 2E1 substrates in the Ames test with the metabolic competent S. typhimurium strain YG7108pin3ERb_5_. Toxicology 228(1):66–76.16978761
Entz RC, Diachenko GW. 1988. Residues of volatile halocarbons in margarines. Food Addit Contam 5:267–276.3396733
Entz RC, Hollifield HC. 1982. Headspace gas chromatographic analysis of foods for volatile halocarbons. J Agric Food Chem 30:84–88.
EPA. 1980. Hazardous waste management system: Identification and listing of hazardous waste: Interim rule. U.S. Environmental Protection Agency. Fed Regist 45:78530–78550.
EPA. 1982a., Methods for organic chemical analysis of municipal and industrial wastewater. Test method: Purgeable halocarbons - Method 601 and Purgeables - Method 624. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory. EPA600482057, 601-l to 601-10 and 624-1 to 624-12.
EPA. 1982b. Test methods for evaluating solid waste. Physical/chemical methods. Method 8010-Halogenated volatile organics. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response, 8010-1 to 8010-12.
EPA. 1985. Designation, reportable quantities, and notification. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.
EPA. 1987. Health advisories for 25 organics. U.S. Environmental Protection Agency, Office of Drinking Water. PB87-2355781AS.
EPA. 1988. Toxic chemical release reporting: Community right-to-know. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372. Fed Regist 53(30):4500–4554.
EPA. 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development. EPA600890066A. PB90238890.
EPA. 1991. Hazardous waste and superfund programs; amendment to preambles published at 54 FR 33418 (August 14, 1989) and 54 FR 50968 (December 11, 1989). U.S. Environmental Protection Agency. Fed Regist 56:643–645.
EPA. 1995. EPA Office of Compliance sector notebook project. Profile of the dry cleaning industry. Washington, DC: U.S. Environmental Protection Agency, Office of Compliance, Office of Enforcement and Compliance Assurance. EPA310R95001. http://www.epa.gov/compliance/resources/publications/assistance/sectors/notebooks/dryclng.pdf. October 14, 2014.
EPA. 1996. Air quality; revision to definition of volatile organic compounds- exclusion of perchloroethylene. Fed Regist 61(26):4587–4591. https://www.gpo.gov/fdsys/pkg/FR-1996-02-07/html/96-2495.htm. June 07, 2018.
EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC. U.S. Environmental Protection Agency. EPA630R96012.
EPA. 1998. RCRA waste minimization PBT priority chemical list. U.S. Environmental Protection Agency. Fed Regist 63 FR 60332. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 1999a. Compendium of methods for the determination of toxic organic compounds in ambient air. Second edition. Compendium Method T0-15. Determination of volatile organic compounds (VOCs) in air collected in specially-prepared canisters and analyzed by gas chromatography/mass spectrometry (GC/MS). Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development. EPA625R96010b.
EPA. 1999b. Compendium of methods for the determination of toxic organic compounds in ambient air. Second edition. Compendium Method T0-17. Determination of volatile organic compounds in ambient air using active sampling onto sorbent tubes. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development. EPA625R96010b.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986).
EPA. 2006. National perchloroethylene air emission standards for dry cleaning facilities. Final rule. Fed Regist 71(144):42723–42746.
EPA. 2007. Definition of hazardous waste. U.S. Environmental Protection Agency 40 CFR 261.3, 34–41. http://www.gpo.gov/fdsys/pkg/CFR-2007-title40-vol25/pdf/CFR-2007-title40-vol25-sec261-3.pdf September 9, 2014.
EPA. 2009a. Drinking water contaminant candidate list. U.S. Environmental Protection Agency. Fed Regist 74 FR 51850:51850-51862. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2009b. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water. EPA816F090004. http://water.epa.gov/drink/contaminants/upload/mcl-2.pdf. April 24, 2013.
EPA. 2009c. National recommended water quality criteria. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Office of Science and Technology. http://water.epa.gov/scitech/swguidance/standards/criteria/current/index.cfm. April 24, 2013.
EPA. 2009d. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water. EPA816F090004. http://water,epa.gov/drink/contaminants/upload/mcl-2.pdf. April 24, 2013.
EPA. 2011. Background indoor air concentrations of volatile organic compounds in North American residences (1990-2005): A compilation of statistics for assessing vapor intrusion. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response. EPA530R10001.
EPA. 2012a. Toxicological review of tetrachloroethylene (perchloroethylene). Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epg.gov/ncea/iris/iris_documents/documents/toxreviews/0106tr.pdf. May 30, 2018.
EPA. 2012b. Designated as hazardous substances in accordance with section 311(b)(2)(a) of the Clean Water Act. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 116.4. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012c. Drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA822S12001. http://water.epa.gov/drink/standards/hascience.cfm. April 24, 2013.
EPA. 2012d. Identification and listing of hazardous waste. Hazardous constituents. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261, Appendix VIII. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012e. Reportable quantities of hazardous substances designated pursuant to section 311 of the Clean Water Act. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012f. Standards for owners and operators of hazardous waste TSD facilities. Groundwater monitoring list. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264, Appendix IX. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012g. Superfund, emergency planning, and community right-to-know programs. Designation, reportable quantities, and notifications. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012h. Superfund, emergency planning, and community right-to-know programs. Toxic chemical release reporting. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012i. Superfund, emergency planning, and community right-to-know programs. Extremely hazardous substances and their threshold planning quantities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 355, Appendix A. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012j. Toxic Substances Control Act. Chemical lists and reporting periods. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 712.30. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012k. Toxic Substances Control Act. Health and safety data reporting. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 716.120. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012l. Vapor intrusion database. http://www.epa.gov/oswer/vaporintrusion/vi_data.html. January 24, 2014.
EPA. 2012m. Petroleum hydrocarbons and chlorinated hydrocarbons differ in their potential for vapor intrusion. Washington, DC: U.S. Environmental Protection Agency, Office of Underground Storage Tanks.
EPA. 2012n. Conceptual model scenarios for the vapor intrusion pathway. U.S. Environmental Protection Agency. EPA530R10003. http://www.epa.gov/sites/production/files/2015-09/documents/vi-cms-v11final-2-24-2012.pdf. February 24, 2016.
EPA. 2013a. Acute exposure guideline levels (AEGLs). Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://www.epa.gov/oppt/aegl/. April 24, 2013.
EPA. 2013b. Hazardous air pollutants. Clean Air Act. U.S. Environmental Protection Agency. United States Code 42 USC 7412. http://www.epa.gov/ttn/atw/orig189.html. April 24, 2013.
EPA. 2013c. National ambient air quality standards (NAAQS). Washington, DC: U.S. Environmental Protection Agency, Office of Air and Radiation. http://www.epa.gov/air/criteria.html. April 24, 2013.
EPA. 2013d. Inert ingredients permitted for use in nonfood pesticide products. Washington, DC: U.S. Environmental Protection Agency. http://iaspub.epa.gov/apex/pesticides/f?p=124:1. April 24, 2013.
EPA. 2013e. Master testing list. Washington, DC: U.S. Environmental Protection Agency, Office of Pollution and Prevention and Toxics. http://www.epa.gov/opptintr/chemtest/pubs/mtl.html. April 24, 2013.
EPA. 2013f. Non-confidential 2006 IUR records by chemical, including manufacturing, processing and use information. U.S. Environmental Protection Agency. http://cfpub.epa.gov/iursearch/2006_iur_companyinfo.cfm?chemid=3752&outchem=both. July 02, 2013.
EPA. 2013g. Dry cleaning emission standards. U.S. Environmental Protection Agency. http://www.epa.gov/drycleaningrule/basic.html. July 02, 2013.
EPA. 2013h. Air toxics data. Tetrachloroethylene. Air toxics-data analysis. U.S. Environmental Protection Agency. http://www.epa.gov/ttnamti1/toxdat.html#data. March 19, 2013.
EPA. 2015a. Chemical data access tool (CDAT). 2012 Chemical data reporting (CDR), ethene, 1,1,2,2-tetrachloro-. U.S. Environmental Protection Agency. http://java.epa.gov/oppt_chemical_search/. December 4, 2015.
EPA. 2015b. Technology transfer network. Clearinghouse for inventories & emissions factors. National Emissions Inventory (NEI) air pollutant emissions trends data. U.S. Environmental Protection Agency. http://www3.epa.gov/ttnchie1/trends/. December 7, 2015.
EPA. 2018. Air quality system (AQS). Data files. Annual summary data. U.S. Environmental Protection Agency. https://www.epa.gov/aqs. December 11, 2018.
Eskenazi B, Fenster L, Hudes M, . 1991a. A study of the effect of perchloroethylene exposure on the reproductive outcomes of wives of dry cleaning workers. Am J Ind Med 20:593–600.1793102
Eskenazi B, Wyrobek AJ, Fenster L, . 1991b. A study of the effect of perchloroethylene exposure on semen quality in dry cleaning workers. Am J Ind Med 20:575–591.1793101
Everatt R, Slapsyte G, Mierauskiene J, . 2013. Biomonitoring study of dry cleaning workers using cytogenetic tests and the comet assay. J Occup Environ Hyg 10(11):609–621. 10.1080/15459624.2013.818238.24116666
*Fagliano J, Berry M, Bove F, . 1990. Drinking water contamination and the incidence of leukemia: An ecologic study. Am J Public Health 80:1209–1212.2400032
FDA. 2013. Everything added to food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://www.accessdata.fda.gov/scripts/fcn/fcnnavigation.cfm?rpt=eafuslisting. April 24, 2013.
*Feldman AL, Johansson AL, Nise G, . 2011. Occupational exposure in parkinsonian disorders: A 43-year prospective cohort study in men. Parkinsonism Relat Disord 17(9):677–682. 10.1016/j.parkreldis.2011.06.009.21733735
Feldman RG, Chirico-Post J, Proctor SP. 1988. Blink reflex latency after exposure to tetrachloroethylene in well water. Pittsburgh, PA: Meeting on Epidemiology in Environmental Health held at the First International Symposium on Environmental Epidemiology, June 3–5, 1987. Arch Environ Health 42:143–148.
Ferrario JB, Lawler GC, Deleon IR, . 1985. Volatile organic pollutants in biota and sediments of Lake Pontchartrain. Bull Environ Contam Toxicol 34:246–255.3978262
Ferroni C, Selis L, Mutti A, . 1992. Neurobehavioral and neuroendocrine effects of occupational exposure to perchloroethylene. Neurotoxicology 13:243–248.1508425
Fisher J, Mahle D, Bankstron L, . 1997. Lactational transfer of volatile chemicals in breast milk. Am Ind Hyg Assoc J 58(6):425–431.9183837
Folkes D, Wertz W, Kurtz J, . 2009. Observed spatial and temporal distributions of CVOCs at Colorado and New York vapor intrusion sites. Ground Water Monit Remed 29(1):70–80.
Fomon SJ. 1966. Body composition of the infant: Part 1: The male reference infant. In: Faulkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35(Suppl 5):1169–1175.7081099
Forand SP, Lewis-Michl EL, Gomez MI. 2012. Adverse birth outcomes and maternal exposure to trichloroethylene and tetrachloroethylene through soil vapor intrusion in New York State. Environ Health Perspect 120(4):616–621.22142966
Franchini I, Cavotorta A, Falzoi M, . 1983. Early indicators of renal damage in workers exposed to organic solvents. Int Arch Occup Environ Health 52:1–9.6603422
Frantz SW, Watanabe PG. 1983. Tetrachloroethylene: Balance and tissue distribution in male Sprague-Dawley rats by drinking water administration. Toxicol Appl Pharmacol 69:66–72.6857689
Fredriksson A, Danielsson BRG, Eriksson P. 1993. Altered behavior in adult mice orally exposed to tri- and tetrachloroethylene as neonates. Toxicol Lett 66:13–19.8427017
Freedman DL, Gossett JM. 1989. Biological reductive dechlorination of tetrachloroethylene and trichloroethylene to ethylene under methanogenic conditions. Appl Environ Microbial 55:2144–2151.
Friberg L, Kylin B, Nystrom A. 1953. Toxicities of trichloroethylene and tetrachloroethylene and Fujiwara’s pyridine-alkali reaction. Acta Pharmacol Toxicol 9:303–312.
Friesel P, Milde G, Steiner B. 1984. Interactions of halogenated hydrocarbons with soils. Fresenius Z Anal Chem 319:160–164.
Gallagher LG, Vieira VM, Ozonoff D, . 2011. Risk of breast cancer following exposure to tetrachloroethylene-contaminated drinking water in Cape Cod, Massachusetts: Reanalysis of a case-control study using a modified exposure assessment. Environ Health 10:47.21600013
Garetano G, Gochfeld M. 2000. Factors influencing tetrachloroethylene concentrations in residences above dry-cleaning establishments. Arch Environ Health 55(1):59–68.10735522
Gargas ML, Burgess RJ, Voisard DE, . 1986. Partition coefficients of low molecular weight volatile chemicals in various liquids and tissues. Wright-Patterson Air Force Base, OH: Armstrong Aerospace Medical Research Laboratory, Toxic Hazards Division, Biochemistry Branch.
Gargas ML, Burgess RJ, Voisard DE, . 1989. Partition coefficients of low-molecular-weight volatile chemicals in various liquids and tissues. Toxicol Appl Pharmacol 98:87–99.2929023
Garnier R, Bedouin J, Pepin G, . 1996. Coin-operated dry cleaning machines may be responsible for acute tetrachloroethylene poisoning: Report of 26 cases including one death. Clin Toxicol 34(2):191–197.
Gay BW Jr, Hanst PL, Bulfalini JJ, . 1976. Atmospheric oxidation of chlorinated ethylenes. Environ Sci Technol 10:58–67.
Gearhart JM. Mahle DA, Greene RJ. 1993. Variability of physiologically based pharmacokinetic (PBPK) model parameters and their effects on PBPK model predictions in a risk assessment for perchloroethylene. Toxicol Lett 68:131–144.8516760
Gennari P, Naldi M, Motta R, . 1992. Gamma-glutamyltransferase isoenzyme pattern in workers exposed to tetrachloroethylene. Am J Ind Med 21:661–671.1351699
Germolec DR, Yang RSH, Ackermann MF, . 1989. Toxicology studies of a chemical mixture of 25 groundwater contaminants: II. Immunosuppression in B6C3F_1_ mice. Fundam Appl Toxicol 13:377–387.2515087
Getz KD, Janulewicz PA, Rowe S, . 2012. Prenatal and early childhood exposure to tetrachloroethylene and adult vision. Environ Health Perspect 120(9):1327–1332.22784657
Ghantous H, Danielsson BRG, Dencker L, . 1986. Trichloroacetic acid accumulates in murine amniotic fluid after tri- and tetrachloroethylene inhalation. Acta Pharmacol Toxicol 58:105–114.
Ghittori S, Imbraini M, Pezzagno G. 1987. The urinary concentration of solvents as a biological indicator of exposure: Proposal for the biological equivalent exposure limit for nine solvents. Am Ind Hyg Assoc J 48:786–790.3687738
*Gilboa SM, Desrosiers TA, Lawson C, . 2012. Association between maternal occupational exposure to organic solvents and congenital heart defects, National Birth Defects Prevention Study, 1997-2002. Occup Environ Med 69(9):628–635. 10.1136/oemed-2011-100536.22811060
Gimmi T, Fluehler H, Studer B, . 1993. Transport of volatile chlorinated hydrocarbons in unsaturated aggregated media. Water Air Soil Pollut 68:291–305.
Giovannini L, Guglielmi G, Casini T, . 1992. Effect of ethanol chronic use on hepatotoxicity in rats exposed to tetrachloroethylene. Int J Tiss React 14(6):281–285.
Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect 101(Supp 2):65–71.7902273
*Glass DC, Heyworth J, Thomson AK, . 2015. Occupational exposure to solvents and risk of breast cancer. Am J Ind Med 58(9):915–922. 10.1002/ajim.22478.26010434
Gobba F. 2000. Color vision: A sensitive indicator of exposure to neurotoxins. Neurotoxicology 21(5):857–862.11130291
Gobba F, Righi E, Fantuzzi G, . 1998. Two-year evolution of perchloroethylene-induced color-vision loss. Arch Environ Health 53(3):196–198.9814715
Gold LS, Milliken K, Stewart P, . 2010. Occupation and multiple myeloma: An occupation and industry analysis. Am J Ind Med 53:768–779.20623662
Gold LS, Stewart PA, Milliken K, . 2011. The relationship between multiple myeloma and occupational exposure to six chlorinated solvents. Occup Environ Med 68(6):391–399.20833760
Goldberg ME, Johnson HE, Pozzani UC, . 1964. Effect of repeated inhalation of vapors of industrial solvents on animal behavior. I. Evaluation of nine solvent vapors on pole-climb performance in rats. Am Ind Hyg Assoc J 25:369–375.14194199
Goldman SM, Quinlan PJ, Ross GW, . 2012. Solvent exposures and Parkinson disease risk in twins. Ann Neurol 71(6):776–784.22083847
Goldsworthy TL, Popp JA. 1987. Chlorinated hydrocarbon-induced peroxisomal enzyme activity in relation to species and organ carcinogenicity. Toxicol Appl Pharmacol 88:225–233.3564041
Goldsworthy TL, Lyght O, Burnett VL, . 1988. Potential rate of α-2μ-globulin, protein droplet accumulation, and cell replication in the renal carcinogenicity of rats exposed to trichloroethylene, perchloroethylene, and pentachloroethane. Toxicol Appl Pharmacol 96:367–379.2461605
Gossett JM. 1987. Measurement of Henry’s law constants for C_1_ and C_2_ chlorinated hydrocarbons. Environ Sci Technol 21:202–208.
Green SM, Khan MF, Kaphalia BS, . 2001. Immunohistochemical localization of trichloroacylated protein adducts in tetrachloroethene-treated mice. J Toxicol Environ Health A 63(2):145–157.11393800
Green T. 1990. Species differences in carcinogenicity: The role of metabolism in human risk evaluation. Teratog Carcinog Mutagen 10:103–113.1973849
Green T, Odum J, Nash JA, . 1990. Perchloroethylene-induced rat kidney tumors: An investigation of the mechanisms involved and their relevance to humans. Toxicol Appl Pharmacol 103:77–89.1969182
Gregersen P. 1988. Neurotoxic effects of organic solvents in exposed workers: Two controlled follow-up studies after 5.5 and 10.6 years. Am J Ind Med 14:681–701.2852897
Gregersen P, Angelso B, Nielsen TE, . 1984. Neurotoxic effects of organic solvents in exposed workers: An occupational neuropsychological and neurological investigation. Am J Ind Med 5:201–225.6322581
Greim H, Bonse G, Radwan Z, . 1975. Mutagenicity in vitro and potential carcinogenicity of chlorinated ethylenes as a function of metabolic oxirane formation. Biochem Pharmacol 24:2013–2017.1108881
Grob K, Frauenfelder C, Artho A. 1990. Uptake by foods of tetrachloroethylene, trichloroethylene, toluene, and benzene from air. Z Lebensm Unters Forsch 191:435–441.2103659
Guberan E, Fernandez J. 1974. Control of industrial exposure to tetrachloroethylene by measuring alveolar concentrations: Theoretical approach using a mathematical model. Br J Ind Med 31:159–167.4830767
Gulyas H, Hemmerling L. 1990. Tetrachloroethene air pollution originating from coin-operated dry cleaning establishments. Environ Res 53:90–99.2226380
Gummin DD. 2015. Hydrocarbons. In: Hoffman RS, Lewin NA, Goldfrank LR, . eds. Goldfrank’s toxicologic emergencies. 10th ed. New York NY: McGraw-Hill Education, 309–310, 1334.
Guo Z, Tichenor BA, Mason MA, . 1990. The temperature dependence of the emission of perchloroethylene from dry cleaned fabrics. Environ Res 52:107–115.2351125
Guyton KZ, Hogan KA, Scott CS, . 2014. Human health effects of tetrachloroethylene: Key findings and scientific issues. Environ Health Perspect 122(4):325–334. 10.1289/ehp.1307359.24531164
Guzelian PS, Henry CJ, Olin SS. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences and Press Institute Press.
*Haddad LM, Winchester JF. 1990. Elimination of poison from the eyes, skin and gastrointestinal tract. In: Clinical management of poisoning and drug overdose. Second edition. Philadelphia, PA: W.B. Saunders Company, Harcourt Brace Jovanovich, Inc., 13–20.
Hadkhale K, Martinsen JI, Weiderpass E, . 2017. Occupational exposure to solvents and bladder cancer: A population-based case control study in Nordic countries. Int J Cancer 140(8):1736–1746. 10.1002/ijc.30593.28032642
Haerer AF, Udelman HD. 1964. Acute brain syndrome secondary to tetrachloroethylene ingestion. Am J Psychiatry 12:78–79.
Hake CL, Stewart RD. 1977. Human exposure to tetrachloroethylene: Inhalation and skin contact. Environ Health Perspect 21:231–238.612448
Hamada T, Tanaka H. 1995. Transfer of methyl chloroform, trichloroethylene and tetrachloroethylene to milk, tissues and expired air following intraruminal or oral administration in lactating goats and milk-fed kids. Environ Pollut 87(3):313–318.15091581
Hanioka N, Jinno H, Toyo’oka T, . 1995. Induction of rat liver drug-metabolizing enzymes by tetrachloroethylene. Arch Environ Contam Toxicol 28:273–280.7726643
Hardin BD, Bond GP, Sikov MR, . 1981. Testing of selected workplace chemicals for teratogenic potential. Scand J Work Environ Health 7(Suppl 4):66–75.7330632
Harkov R, Kebbekus B, Bozzelli JW, . 1984. Comparison of selected volatile organic compounds during the summer and winter at urban sites in New Jersey. Sci Total Environ 38:259–274.
Hartmann A, Speit G. 1995. Genotoxic effects of chemicals in the single cell gel (SCG) test with human blood cells in relation to the induction of sister-chromatid exchanges (SCE). Mutat Res 346(1):49–56.7530329
Hartwell TD, Pellizzari ED, Perritt RL, . 1987. Comparison of volatile organic levels between sites and seasons for the total exposure assessment methodology (TEAM) study. Atmos Environ 21:2413–2424.
Hasanen E, Soininen V, Pyysalo M, . 1979. The occurrence of aliphatic chlorine and bromine compound in automobile exhaust. Atmos Environ 13:1217–1219.
Hattis D, White P, Koch P. 1993. Uncertainties in pharmacokinetic modeling for perchloroethylene: II. Comparison of model predictions with data for a variety of different parameters. Risk Anal 13(6):599–610.8310161
Hattis D, White P, Marmorstein L, . 1990. Uncertainties in pharmacokinetic modeling for perchloroethylene. I. Comparison of model structure, parameters, and predictions for low-dose metabolism rates for models derived by different authors. Risk Anal 10(3):449–458.2236748
Haworth S, Lawlor T, Mortelmans K, . 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen Supplement 1:3–142.
Hayes JR, Condie LW Jr, Borzelleca JF. 1986. The subchronic toxicity of tetrachloroethylene (perchloroethylene) administered in the drinking water of rats. Fundam Appl Toxicol 7:119–125.3732662
HazDat. 2007. Trichloroethylene. HazDat Database: ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
*Health Canada. 2014. Tetrachloroethylene in drinking water. Document for public comment. http://www.hc-sc.gc.ca/ewh-semt/alt_formats/pdf/consult/_2014/tetrachloroethylene/consult-eng.pdf. May 10, 2016.
Heikes DL, Hopper ML. 1986. Purge and trap method for determination of fumigants in whole grains, milled grain products, and intermediate grain-based foods. J Assoc Off Anal Chem 69:990–998.3542956
*Heineman EF, Cocco P, Gomez MR, . 1994. Occupational exposure to chlorinated aliphatic hydrocarbons and risk of astrocytic brain cancer. Am J Ind Med 26:155–169.7977393
Hemminki K, Saloniemi I, Luoma K, . 1980. Transplacental carcinogens and mutagens: Childhood cancer, malformation and abortions as risk indicators. J Toxicol Environ Health 6:1115–1126.7463506
Henschler D. 1977. Metabolism and mutagenicity of halogenated olefins: A comparison of structure and activity. Environ Health Perspect 21:61–64.348459
Hickman JC. 2000. Tetrachloroethylene. In: Kirk Othmer encyclopedia of chemical technology. John Wiley & Sons, Inc., 1–9.
Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
Hook EB. 1982. Perspectives in mutation epidemiology: 2. Epidemiologic and design aspects of studies of somatic chromosome breakage and sister-chromatic exchange. Mutat Res 99:373–382.
Hoyt SD, Smith VL. 1991. Measurement of toxic organic compounds in ambient air using EPA method TO-14. In: Capillary chromatography - The applications. Jennings W, Nikelly JG, eds. Heidelberg: Huthig Buch Verlag 83–94.
HSDB. 2013. Tetrachloroethylene. Hazardous Substances Data Bank. National Library of Medicine, http://toxnet.nlm.nih.gov. May 09, 2013.
Hunkeler D, Aravena R, Butler BJ. 1999. Monitoring microbial dechlorination of tetrachloroethene (PCE) in groundwater using compound-specific stable carbon isotope ratios: Microcosm and field studies. Environ Sci Technol 33(16):2733–2738.
IARC. 1979. IARC monographs on the evaluation of the carcinogenic risk of chemicals in humans. Tetrachloroethylene. Lyon, France: World Health Organization, 20:491–514.
IARC. 2014. Tetrachloroethylene. In: Trichloroethylene, tetrachloroethylene, and some other chlorinated agents. Vol. 106. IARC Monographs on the evaluation of carcinogenic risks to humans. World Health Organization, International Agency for Research on Cancer, 219–351. https://monographs.iarc.fr/ENG/Monographs/vol106/mono106-F01-F02.pdf. April 6, 2016.
ICRP. 2002. Basic anatomical and physiological data for use in radiological protection: Reference values. A report of age-and gender-related differences in the anatomical and physiological characteristics of reference individuals. International Commission on Radiological Protection. Ann ICRP 32(Publication 89):5–265.14506981
Ikeda M, Imamura T. 1973. Biological half-life of trichloroethylene and tetrachloroethylene in human subjects. Int Arch Arbeitsmed 31:209–224.4593976
Ikeda M, Koizuma A, Watanabe T, . 1980. Cytogenetic and cytokinetic investigations on lymphocytes from workers occupationally exposed to tetrachloroethylene. Toxicol Lett 5:251–256.7466854
Ikeda M, Ohtsuji H, Imamura T, . 1972. Urinary excretion of total trichloro-compounds, trichloroethanol, and trichloroacetic acid as a measure of exposure to trichloroethylene and tetrachloroethylene. Br J Ind Med 29:328–333.5044605
Imbriani M, Ghittori S, Pezzagno G, . 1988. Urinary excretion of tetrachloroethylene (perchloroethylene) in experimental and occupational exposure. Arch Environ Health 43:292–298.3415356
IRIS. 2012. Tetrachloroethylene. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/. April 24, 2013.
Isalou M, Sleep BE, Liss SN. 1998. Biodegradation of high concentrations of tetrachloroethene in a continuous flow column system. Environ Sci Technol 32(22):3579–3585.
Isenschmid DS, Cassin BJ, Hepler BR, . 1998. Tetrachloroethylene intoxication in an autoerotic fatality. J Forensic Sci 43(1):231–234.9456554
Itoh N, Kutsuna S, Ibusuki T. 1994. A product study of the OH radical initiated oxidation of perchloroethylene and trichloroethylene. Chemosphere 28(11):2029–2040.
ITRC. 2003. An introduction to characterizing sites contaminated with DNAPLs. Interstate Technology and Regulatory Council, Dense Nonaqueous Phase Liquids Team.
Jakobson I, Wahlberg JE, Holmberg B, . 1982. Uptake via the blood and elimination of 10 organic solvents following epicutaneous exposure of anesthetized guinea pigs. Toxicol Appl Pharmacol 63:181–187.7089968
James KJ, Stack MA. 1996. The determination of volatile organic compounds in soils using solid phase microextraction with gas chromatography-mass spectrometry. J High Resolut Chromatogr 19(9):515–519.
Jang JY, Droz PO. 1997. Ethnic differences in biological monitoring of several organic solvents. II. A simulation study with a physiologically based pharmacokinetic model. Int Arch Occup Environ Health 70(1):41–50.9258706
Jang JY, Kang S K, Chung HK. 1993. Biological exposure indices of organic solvents for Korean workers. Int Arch Occup Environ Health 65:S219–S222.8406930
Janulewicz PA, White RF, Martin BM, . 2012. Adult neuropsychological performance following prenatal and early postnatal exposure to tetrachloroethylene (PCE)-contaminated drinking water. Neurotoxicol Teratol 34(3):350–359.22522125
Janulewicz PA, Killiany RJ, White RF, . 2013. Structural magnetic resonance imaging in an adult cohort following prenatal and early postnatal exposure to tetrachloroethylene (PCE)-contaminated drinking water. Neurotoxicol Teratol 38:13–20. 10.1016/j.ntt.2013.03.060.23571160
Janulewicz PA, White RF, Winter MR, . 2008. Risk of learning and behavioral disorders following prenatal and early postnatal exposure to tetrachloroethylene (PCE)-contaminated drinking water. Neurotoxicol Teratol 30(3):175–185.18353612
Jeffers PM, Ward LM, Woytowitch LM, . 1989. Homogenous hydrolysis rate constants for selected chlorinated methanes, ethanes, ethenes and propanes. Environ Sci Technol 23:965–969.
*Ji J, Hemminki K. 2006. Socioeconomic/occupational risk factors for lymphoproliferative diseases in Sweden. Ann Epidemiol 16(5):370–376. 10.1016/j.annepidem.2005.09.002.16246580
JISA. 1993. Carcinogenicity study of tetrachloroethylene by inhalation in rats and mice. Japan Industrial Safety Association.
Johnson PC, Ettinger RA. 1991. Heuristic model for predicting the intrusion rate of contaminant vapors into buildings. Environ Sci Technol 25(8):1445–1452.
Johnston JE, Gibson JM. 2013. Spatiotemporal variability of tetrachloroethylene in residential indoor air due to vapor intrusion: A longitudinal, community-based study. J Expo Sci Environ Epidemiol [epub ahead of print].
Johnston JE, Gibson JM. 2014. Spatiotemporal variability of tetrachloroethylene in residential indoor air due to vapor intrusion: a longitudinal, community-based study. J Expo Sci Environ Epidemiol 24(6):564–571. 10.1038/jes.2013.13.23549403
Jonker D, Woutersen RA, Feron VJ. 1996. Toxicity of mixtures of nephrotoxicants with similar or dissimilar mode of action. Food Chem Toxicol 34(11–12):1075–1082.9119318
Jung WT, Fujita M, Sohn DH. 1992. Levels of volatile halogenated hydrocarbons in Tokyo rain and their seasonal, time-series changes. Jpn J Toxicol Environ Health 38:490–497.
Karlsson JE, Rosengren LE, Kjellstrand P, . 1987. Effects of low-dose inhalation of three chlorinated aliphatic organic solvents on deoxyribonucleic acid in gerbil brain. Scand J Work Environ Health 13:453–458.3433047
Katz RM, Jowett D. 1981. Female laundry and dry cleaning workers in Wisconsin. A mortality analysis. Am J Public Health 71:305–307.7468868
Kawakami T, Takano T, Araki R. 1988. Synergistic interaction of tri- and tetra-chloroethylene, hypoxia, and ethanol on the atrioventricular conduction of the perfused rat heart. Ind Health 26:25–33.3360617
Kawasaki M. 1980. Experiences with the test scheme under the chemical control law of Japan: An approach to structure-activity correlations. Ecotoxicol Environ Saf 4:444–454.7472248
Kawata K, Fujieda Y. 1993. Volatile chlorinated hydrocarbons in ambient air at Niigata area. Jpn J Toxicol Environ Health 39(5):474–479.
Kawata K, Tanabe A, Saito S, . 1997. Screening of volatile organic compounds in river sediment. Bull Environ Contam Toxicol 58(6):893–900.9136651
Kearns GL, Abdel-Rahman SM, Alander SW, . 2003. Developmental pharmacology-drug disposition, action, and therapy in infants and children. N Engl J Med 349(12):1157–1167. 10.1056/NEJMra035092.13679531
Keil SL. 1985. Tetrachloroethylene. In: Grayson M, Eckroth P, eds. Kirk-Othmer concise encyclopedia of chemical technology. New York NY: John Wiley and Sons, 754–762.
Kenaga EE. 1980. Predicted bioconcentration factors and soil sorption coefficients of pesticides and other chemicals. Ecotoxicol Environ Saf 4:26–38.7379718
Kendrick JF. 1929. The treatment of hookworm disease with tetrachloroethylene. Am J Trop Med 483–488.
Kezic S, Monster AC, Kruse J, . 2000. Skin absorption of some vaporous solvents in volunteers. Int Arch Occup Environ Health 73(6):415–422.11007346
Kezic S, Monster AC, van de Gevel IA, . 2001. Dermal absorption of neat liquid solvents on brief exposures in volunteers. Am Ind Hyg Assoc J 62(1):12–18.
*Kido K, Shiratori T, Watanabe T, . 1989. Correlation of tetrachloroethylene in blood and in drinking water: A case of well water pollution. Bull Environ Contam Toxicol 43:444–453.2790252
Kido T, Sugaya C, Ikeuchi R, . 2013. The increases in mRNA expressions of inflammatory cytokines by adding cleaning solvent or tetrachloroethylene in the murine macrophage cell line J774.1 evaluated by real-time PCR. Ind Health 51:319–323.23538726
Kim BH, Baek KH, Cho DH, . 2010. Complete reductive dechlorination of tetrachloroethene to ethene by anaerobic microbial enrichment culture developed from sediment. Biotechnol Lett 32(12):1829–1835.20714784
Kinkead ER, Leahy HF. 1987. Evaluation of the acute toxicity of selected groundwater contaminants. Government Reports Announcements & Index (GRA&I). ADA1801984.
Kirchner K, Helf D, Ott P, . 1990. The reaction of OH radicals with 1,1-di, tri- and tetrachloroethylene. Berichte der Bunsengesellschaft fur Physikalische Chemie 94:77–83.
Kjellstrand P, Bjerkemo M, Adler-Maihofer M, . 1985. Effects of solvent exposure on testosterone levels and butyrylcholinesterase activity in mice. Acta Pharmacol Toxicol 57:242–249.
Kjellstrand P, Holmquist B, Kanje M, . 1984. Perchloroethylene: Effects on body and organ weights and plasma butyrylcholinesterase activity in mice. Acta Pharmacol Toxicol 54:414–424.
Klaassen CD, Plaa GL. 1966. Relative effects of various chlorinated hydrocarbons on liver and kidney function in mice. Toxicol Appl Pharmacol 9:139–151.5967557
Klaassen CD, Plaa GL. 1967. Relative effects of various chlorinated hydrocarbons on liver and kidney function in dogs. Toxicol Appl Pharmacol 10:119–131.6031921
Kline SA, McCoy EC, Rosenkranz HS, . 1982. Mutagenicity of chloroalkene epoxides in bacterial systems. Mutat Res 101:115–125.7048080
Kluwe WM, Abdo KM, Huff J. 1984. Chronic kidney disease and organic chemical exposure: Evaluations of causal relationships in humans and experimental animals. Fundam Appl Toxicol 4:899–901.
Kobayashi S, Hutcheon DE, Regan J. 1982. Cardiopulmonary toxicity of tetrachloroethylene. J Toxicol Environ Health 10:23–30.7131586
Koch R, Schlegelmilch R, Wolf HU. 1988. Genetic effects of chlorinated ethylenes in the yeast Saccharomyces cerevisiae. Mutat Res 206:209–216.3050501
Koizumi A. 1989. Potential of physiologically based pharmacokinetics to amalgamate kinetic data of trichloroethylene and tetrachloroethylene obtained in rats and man. Br J Ind Med 46(4):239–249.2713280
Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29(18):4430–4433.2350547
Koppel C, Arndt I, Arendt U, . 1985. Acute tetrachloroethylene poisoning: Blood elimination kinetics during hyperventilation therapy. Clin Toxicol 23:103–115.
Korpela M. 1988. Organic solvents affect rat synaptosome membrane acetylcholinesterase and adenosine triphosphatase in vitro. Arch Toxicol Suppl 12:384–386.
Korpela M, Tahti H. 1986. The effect of selected organic solvents on intact human red cell membrane acetylcholinesterase in vitro. Toxicol Appl Pharmacol 85:257–262.3764913
Krause RJ, Lash LH, Elfarra AA. 2003. Human kidney flavin-containing monooxygenases and their potential roles in cystein S-conjugate metabolism and nephrotoxicity. J Pharmacol Exp Ther 304(1):185–191.12490590
Kringstad KP, Ljungquist PO, deSousa F, . 1981. Identification and mutagenic properties of some chlorinated aliphatic compounds in the spent liquor from Kraft pulp chlorination. Environ Sci Technol 15:562–566.22283948
Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Krost KJ, Pellizzari ED, Walburn SG, . 1982. Collection and analysis of hazardous organic emissions. Anal Chem 54:810–817.
Krotoszynski BK, Bruneau GM, O’Neill HJ. 1979. Measurement of chemical inhalation exposure in urban population in the presence of endogenous effluents. J Anal Toxicol 3:225–234.
Krska R, Taga K, Kellner R. 1993. New IR fiber-optic chemical sensor for in situ measurements of chlorinated hydrocarbons in water. Appl Spectroscopy 47(9):1484–1487.
Krumholz LR, Sharp R, Fishbain SS. 1996. A freshwater anaerobe coupling acetate oxidation to tetrachloroethylene dehalogenation. Appl Environ Microbiol 62(11):4108–4113.8900001
Kukongviriyapan V, Kukongviriyapan U, Stacey NH. 1990. Interference with hepatocellular substrate uptake by 1,1,1-trichloroethane and tetrachloroethylene. Toxicol Appl Pharmacol 102(1):80–90.2296773
Kylin B, Reichard H, Sumegi I, . 1963. Hepatotoxicity of inhaled trichloroethylene, tetrachloroethylene, and chloroform-single exposure. Acta Pharmacol Toxicol 20:16–26.
Kylin B, Sumegi I, Yllner S. 1965. Hepatotoxicity of inhaled trichloroethylene and tetrachloroethylene--long-term exposure. Acta Pharmacol Toxicol 22:379–385.
Kyrklund T, Haglid K. 1991. Brain lipid composition in guinea pigs after intrauterine exposure to perchloroethylene. Pharmacol Toxicol 68:146–148.1852720
Kyrklund T, Alling C, Kjellstrand P, . 1984. Chronic effects of perchloroethylene on the composition of lipid and acyl groups in cerebral cortex and hippocampus of the gerbil. Toxicol Lett 22:343–349.6485008
Kyrklund T, Kjellstrand P, Haglid K. 1987. Brain lipid changes in rats exposed to xylene and toluene. Toxicology 45:123–133.3603578
Kyrklund T, Kjellstrand P, Haglid KG. 1988. Effects of exposure to Freon 11, 1,1,1-trichloroethane or perchloroethylene on the lipid and fatty-acid composition of rat cerebral cortex. Scand J Work Environ Health 14:91–94.3387963
Kyrklund T, Kjellstrand P, Haglid KG. 1990. Long-term exposure of rats to perchloroethylene, with and without a post-exposure solvent-free recovery period: Effects on brain lipids. Toxicol Lett 52:279–285.2389258
Kyyronen P, Taskinen H, Lindbohm ML, . 1989. Spontaneous abortions and congenital malformations among women exposed to tetrachloroethylene in dry cleaning. J Epidemiol Community Health 43:346–351.2614324
Lafuente A, Mallol J. 1986. Thioethers in urine during occupational exposure to tetrachloroethylene. Br J Ind Med 43:68–69.3947566
Lagakos SW, Wessen BJ, Zelen M, . 1986. An analysis of contaminated well water and health effects in Woburn, Massachusetts. J Am Stat Assoc 81:583–614.
Larson CD, Love OT, Jr., Reynolds G. 1983. Tetrachloroethylene leached from lined asbestos-cement pipe into drinking water. J Am Water Works Assoc April 1983:184–190.
Lash LH, Parker JC. 2001. Hepatic and renal toxicities associated with perchloroethylene. Pharmacol Rev 53(2):177–208.11356983
Lash LH, Putt DA, Huang P, . 2007. Modulation of hepatic and renal metabolism and toxicity of trichloroethylene and perchloroethylene by alterations in status of cytochrome P450 and glutathione. Toxicology 235(1–2):11–26.17433522
Lash LH, Qian W, Putt DA, . 1998. Glutathione conjugation of perchloroethylene in rats and mice in vitro: Sex-, species-, and tissue-dependent differences. Toxicol Appl Pharmacol 150(1):49–57.9630452
Lash LH, Qian W, Putt DA, . 2002. Renal toxicity of perchloroethylene and S-(1,2,2-trichlorovinyl)glutathione in rats and mice: Sex- and species-dependent differences. Toxicol Appl Pharmacol 179(3):163–171.11906246
Lash LH, Qian W, Xu Y, . 1996. Renal and hepatic metabolism and cytotoxicity of perchloroethylene (PER) by GSH conjugation. Toxicologist 30(1):314.
Lauwerys R, Herbrand J, Buchet JP, . 1983. Health surveillance of workers exposed to tetrachloroethylene in dry cleaning shops. Int Arch Occup Environ Health 52:69–77.6874093
Lee LJ, Chan C, Chung C. 2002. Health risk assessment on residents exposed to chlorinated hydrocarbons contaminated in groundwater of a hazardous waste site. J Toxicol Environ Health Part A 65:219–235.
Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Lehmann I, Rehwagen M, Dietz U, . 2001. Enhanced in vivo lgE production and T cell polarization toward the type 2 phenotype in association with indoor exposure to VOC: Results of the LARS study. Int J Hyg Environ Health 204:211–221.11833293
Lehmann I, Thoelke A, Rehwagen M, . 2002. The influence of maternal exposure to volatile organic compounds on the cytokine secretion profile of neonatal T cells. Environ Toxicol 17(3):203–210.12112628
Leibman KC, Ortiz E. 1977. Metabolism of halogenated ethylenes. Environ Health Perspect 21:91–97.612463
*Leikin JB, Paloucek FP. 2008. Tetrachloroethylene. In: Poisoning and toxicology handbook, 4th ed. Hudson, OH: Lexi-Comp, Inc., 853.
Leung H. 1993. Physiologically-based pharmacokinetic modelling. In: Ballantyne B, Marrs T, Turner P, eds. General and applied toxicology. Vol. 1. New York NY: Stockton Press, 153–164.
Levine B, Fierro MF, Goza SW, . 1981. A tetrachloroethylene fatality. J Forensic Sci 26:206–209.7205186
LHWMP. 2013. Evaluating vapor leak detectors for use in “PERC” dry cleaners. Final report. King County, WA: Local Hazardous Waste Management Program.
Lide DR, ed. 1990. CRC Handbook of chemistry and physics. 71st ed. Ann Arbor, MI: CRC Press, Inc., 3–242.
Lide DR. 2008. Tetrachloroethylene. In: CRC handbook of chemistry and physics. 88th ed. Boca Raton, FL: CRC Press, 3–470.
Ligocki MP, Leuenberger C, Pankow JF. 1985. Trace organic compounds in rain-II. Gas scavenging of neutral organic compounds. Atmos Environ 19:1609–1617.
Lillford L, Beevers C, Bowen D, . 2010. RE: DNA damage detected by the alkaline comet assay in the liver of mice after oral administration of tetrachloroethylene. Mutagenesis 25:133–138.19892777
Lin YS, Egeghy PP, Rappaport SM. 2008. Relationships between levels of volatile organic compounds in air and blood from the general population. J Expo Sci Environ Epidemiol 18(4):421–429. 10.1038/sj.jes.7500635.18059425
Lindbohm ML, Taskinen H, Sallmén M, . 1990. Spontaneous abortions among women exposed to organic solvents. Am J Ind Med 17:449–463.2327413
Ling S, Lindsay WA. 1971. Perchloroethylene burns (Letter). Br Med J 3:115.
Lipworth L, Sonderman JS, Mumma MT, . 2011. Cancer mortality among aircraft manufacturing workers: An extended follow-up. J Occup Environ Med 53(9):992–1007.21866047
Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4(2–3):301–324.351201
Loizou GD. 2001. The application of physiologically based pharmacokinetic modelling in the analysis of occupational exposure to perchloroethylene. Toxicol Lett 124(1–3):59–69.11684358
*Lorenz H, Weber E, Omlor A, . 1990. [Evidence of cerebral lesions caused by tetrachloroethylene]. Zbl Arbeitsmed 40:355–364. (German)
Lovell D. 2010. Is tetrachloroethylene genotoxic or not? Mutagenesis 25(5):443–446.20634266
Lu C, Bjerg PL, Zhang F, . 2011. Sorption of chlorinated solvents and degradation products on natural clayey tills. Chemosphere 83(11):1467–1474.21459403
Lucas D, Herve A, Lucas R, . 2015. Assessment of exposure to perchloroethylene and its clinical repercussions for 50 dry-cleaning employees. J Occup Environ Hyg 12(11):767–773. 10.1080/15459624.2015.1048346.26011697
Lukaszewski T. 1979. Acute tetrachloroethylene fatality. Clin Toxicol 15:411–415.540489
Lurker PA, Clark CS, Elia VJ. 1982. Atmospheric release of chlorinated organic compounds from the activated sludge process. J Water Pollut Control Fed 54:1566–1573.
*Lynge E. 1994. Danish cancer registry as a resource for occupational research. J Occup Med 36(11):1169–1173.
Lynge E, Thygesen L. 1990. Primary liver cancer among women in laundry and dry cleaning work in Denmark. Scand J Work Environ Health 16:108–112.2353193
Lynge E, Andersen A, Rylander L, . 2006. Cancer in persons working in dry cleaning in the Nordic countries. Environ Health Perspect 114(2):213–219.16451857
Lynge E, Carstensen B, Andersen O. 1995. Primary liver cancer and renal cell carcinoma in laundry and dry cleaning workers in Denmark. Scand J Work Environ Health 21:293–295.8553005
Ma T-H, Sandhu SS, Peng Y, . 1992. Synergistic and antagonistic effects on genotoxicity of chemicals commonly found in hazardous waste sites. Mutat Res 270:71–77.1383725
Macca I, Carrieri M, Scapellato ML, . 2012. Biological monitoring of exposure to perchloroethylene in dry cleaning workers. Med Lav 103(5):382–393.23077798
MacMahon B. 1986. Comment. J Am Stat Assoc 81(395):597–599.
Mahalingaiah S, Winter MR, Aschengrau A. 2016. Association of prenatal and early life exposure to tetrachloroethylene (PCE) with polycystic ovary syndrome and other reproductive disorders in the Cape Cod health study: A retrospective cohort study. Reprod Toxicol 65:87–94. 10.1016/j.reprotox.2016.07.005.
Mahle DA, Gearhart JM, Godfrey RJ, . 2004. Determination of partition coefficients for a mixture of volatile organic compounds in rats and humans at different life stages. Wright-Patterson Air Force Base, OH: Air Force Research Laboratory, Applied Biotechnology Branch. ADA436299.
Mahle DA, Gearhart JM, Grigsby CC, . 2007. Age-dependent partition coefficients for a mixture of volatile organic solvents in Sprague-Dawley rats and humans. J Toxicol Environ Health A 70(20):1745–1751.17885931
Makide Y, Tominaga T, Rowland FS. 1979. Gas chromatographic analysis of halogenated hydrocarbons in air over Japan. Chem Lett 355–358.
Maloney EK, Waxman DJ. 1999. Trans-activation of PPARα and PPARγ by structurally diverse environmental chemicals. Toxicol Appl Pharmacol 161(2):209–218.10581215
Marco-Urrea E, Gabarrell X, Sarrà M, . 2006. Novel aerobic perchloroethylene degradation by the white-rot fungus Trametes versicolor. Environ Sci Technol 40(24):7796–7802.17256530
Marth E. 1987. Metabolic changes following oral exposure to tetrachloroethylene in subtoxic concentrations. Arch Toxicol 60:293–299.3632354
Matsushima T, Nagano K, Nishizawa T, . 1998. Long term inhalation toxicity studies of five chlorinated hydrocarbons in F344 rats and BDF1 mice. Proceedings of the 1st International Conference of Asian Society of Toxicology, Yokohama, Japan, June 29-July 2, 1997. J Toxicol Sci 23(Suppl 2):296.
Mattei F, Guida F, Matrat M, . 2014. Exposure to chlorinated solvents and lung cancer: Results of the ICARE study. Occup Environ Med 71(10):681–689. 10.1136/oemed-2014-102182.25015929
Mattie DR, Bates GD, Jepson GW, . 1994. Determination of skin: Air partition coefficients for volatile chemicals: Experimental methods and applications. Fundam Appl Toxicol 22:51–57.8125213
Mattsson JL, Albee RR, Yano BL, . 1992. Neurotoxicologic examination of rats exposed to 1,1,2,2-tetrachloroethylene vapor for 13 weeks. The Dow Chemical Company, sponsored by Halogenated Solvents Industry Alliance.
Mattsson JL, Albee RR, Yano BL, . 1998. Neurotoxicologic examination of rats exposed to 1,1,2,2-tetrachloroethylene (perchloroethylene) vapor for 13 weeks. Neurotoxicol Teratol 20(1):83–98.9511173
Matushima T, Hayashi M, Matsuoka A, . 1999. Validation study of the in vitro micronucleus test in a Chinese hamster lung cell line (CHL/IU). Mutagenesis 14(6):569–580.10567032
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74(2–3):135–149.1387742
Mazzullo M, Grilli S, Lattanzi G, . 1987. Evidence of DNA binding activity of perchloroethylene. Res Commun Chem Pathol Pharmacol 58:215–235.2447621
McCarthy MC, Hafner HR, Chinkin LR, . 2007. Temporal variability of selected air toxics in the United States. Atmos Environ 41(34):7180–7194. 10.1016/j.atmosenv.2007.05.037. http://www.sciencedirect.com/science/article/pii/S1352231007004840.
McDonald AD, Armstrong B, Cherry NM, . 1986. Spontaneous abortion and occupation. J Occup Med 28:1232–1238.3806263
McDonald AD, McDonald JC, Armstrong B, . 1987. Occupation and pregnancy outcome. Br J Ind Med 44:521–526.3651350
McDonald GJ, Wertz WE. 2007. PCE, TCE, and TCA vapors in subslab soil, gas, and indoor air: A case study in upstate New York. Ground Water Monit Remed 27(4):86–92.
McDougal JN, Jepson GW, Clewell HJ III, . 1990. Dermal absorption of organic chemical vapors in rats and humans. Fundam Appl Toxicol 14:299–308.2318354
McKernan LT, Ruder AM, Petersen MR, . 2008. Biological exposure assessment to tetrachloroethylene for workers in the dry cleaning industry. Environ Health 7:12.18412959
Meckler LC, Phelps DK. 1966. Liver disease secondary to tetrachloroethylene exposure: A case report. J Am Med Assoc 197:662–663.
Mennear J, Maronpot R, Boorman G, . 1986. Toxicologic and carcinogenic effects of inhaled tetrachloroethylene in rats and mice. Dev Toxicol Environ Sci 12:201–210.3470175
Meyer BR, Fischbein A, Rosenman K, . 1984. Increased urinary enzyme excretion in workers exposed to nephrotoxic chemicals. Am J Med 76:989–998.6731470
Michael LC, Erickson MD, Parks SP, . 1980. Volatile environmental pollutants in biological matrices with a headspace purge technique. Anal Chem 52:1836–1841.7435989
Milde G, Nerger M, Mergler R. 1988. Biological degradation of volatile chlorinated hydrocarbons in groundwater. Meeting on Groundwater Microbiology: Problems and Biological Treatment held at the International Association on Water Pollution Research and Control Symposium, Kuopio, Finland, August 4-6, 1987. Water Sci Technol 20:67–73.
*Miligi L, Costantini AS, Benvenuti A, . 2006. Occupational exposure to solvents and the risk of lymphomas. Epidemiology 17(5):552–561. 10.1097/01.ede.0000231279.30988.4d.16878041
Monster AC. 1986. Biological monitoring of chlorinated hydrocarbon solvents. J Occup Med 28:583–588.3746478
Monster AC. 1988. Biological markers of solvent exposure. Arch Environ Health 43:90–93.3377562
Monster AC, Smolders JFJ. 1984. Tetrachloroethylene in exhaled air of persons living near pollution sources. Int Arch Occup Environ Health 53:331–336.6715057
Monster AC, Boersma G, Steenweg H. 1979. Kinetics of tetrachloroethylene in volunteers: Influence of exposure concentration and work load. Int Arch Occup Environ Health 42:303–309.422271
Monster AC, Regouin-Peeters W, Van Schijndel A, . 1983. Biological monitoring of occupational exposure to tetrachloroethene. Scand J Work Environ Health 9:273–281.6612269
Morgan B. 1969. Dangers of perchloroethylene (Letter). Br Med J 2:513.
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokinet 5(6):485–527.7002417
Morton LM, Slager SL, Cerhan JR, . 2014. Etiologic heterogeneity among non-Hodgkin lymphoma subtypes: The interlymph non-Hodgkin lymphoma subtypes project. Journal of the National Cancer Institute Monographs 48:130–144.
Moser VC, Cheek BM, MacPhail RC. 1995. A multidisciplinary approach to toxicological screening: III. Neurobehavioral toxicity. J Toxicol Environ Health 45:173–210.7783252
Moslen MT, Reynolds ES, Szabo S. 1977. Enhancement of the metabolism and hepatotoxicity of trichloroethylene and perchloroethylene. Biochem Pharmacol 26:369–375.192239
*Motohashi Y, Miyazaki Y, Takano T. 1993. Assessment of behavioral effects of tetrachloroethylene using a set of time-series analyses. Neurotoxicol Teratol 15:3–10.8459786
Motwani JN, Popp SA, Johnson GM, . 1986. Field screening techniques developed under the Superfund program. Management of uncontrolled hazardous waste sites, Hazardous Materials Control Research Institute, Washington, DC, December 1–3, 1986, Silver Spring, MD, 105–109.
Mumtaz M, Fisher J, Blount B, . 2012a. Application of physiologically based pharmacokinetic models in chemical risk assessment. J Toxicol Article ID 904603. 10.1155/2012/904603.
Mumtaz MM, Ray M, Crowell SR, . 2012b. Translational research to develop a human PBPK models tool kit—volatile organic compounds (VOCs). J Toxicol Environ Health Part A 75(1):6–24.
Murakami K, Horikawa K. 1995. The induction of micronuclei in mice hepatocytes and reticulocytes by tetrachloroethylene. Chemosphere 31(7):3733–3739.8528655
Murphy CD, Moore RM, White RL. 2000. An isotopic method for determining production of volatile organohalogens by marine microalgae. Limnol Oceanogr 45(8):1868–1871.
Mutti A, Franchini I. 1987. Toxicity of metabolites to dopaminergic systems and the behavioral effects of organic solvents. Br J Ind Med 44:721–723.3318914
Mutti A, Alinovi R, Bergamaschi E, . 1992. Nephropathies and exposure to perchloroethylene in dry-cleaners. Lancet 340(8813):189–193.1353133
Nagano K, Nishizawa T, Yamamoto S, . 1998. Inhalation carcinogenesis studies of six halogenated hydrocarbons in rats and mice. In: Chiyoiani K, Hosoda Y, Aizawa Y, eds. Advances in the prevention of occupational respiratory diseases. Elsevier Science 741–746.
Nakahama T, Fukuhara M, Inouye Y. 1997. Volatile halogenated hydrocarbons in ambient air and the metabolites in human urine in an urban area. Jpn J Toxicol Environ Health 43(5):280–284.
Nakatsuka H, Watanabe T, Takeuchi Y, . 1992. Absence of blue-yellow color vision loss among workers exposed to toluene or tetrachloroethylene, mostly at levels below occupational exposure limits. Int Arch Occup Environ Health 64:113–117.1399020
Narotsky MG, Kavlock RJ. 1995. A multidisciplinary approach to toxicological screening: II. Development toxicity. J Toxicol Environ Health 45:145–171.7783251
NAS. 1980. Drinking water and health. Volume 3. Washington, DC: National Academy of Science, Safe Drinking Water Committee, National Academy Press.
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: 15–35.
Nazaroff WW, Weschler CJ. 2004. Cleaning products and air fresheners: Exposure to primary and secondary air pollutants. Atmos Environ 38(18):2841–2865.
NCI. 1977. Bioassay of tetrachloroethylene for possible carcinogenicity. National Cancer Institute. U.S. Department of Health, Education, and Welfare, Public Health Service, National Institutes of Health, DHEW Publ (NIH) 77–813.
Neely WB, Branson DR, Blau GE. 1974. Partition coefficients to measure bioconcentration potential of organic chemicals in fish. Environ Sci Technol 8:1113–1115.
Nelson BK, Taylor BJ, Setzer JV, . 1980. Behavioral teratology of perchloroethylene in rats. J Environ Pathol Toxicol 3:233–250.
Neta G, Stewart PA, Rajaraman P, . 2012. Occupational exposure to chlorinated solvents and risks of glioma and meningioma in adults. Occup Environ Med 69(11):793–801. 10.1136/oemed-2012-100742.22864249
Newcombe R. 2000. Perchloroethylene (PCE) in dry cleaning establishments. http://www.webpages.uidaho.edu/etox/resources/case_studies/pce_dry.pdf. July 02, 2013.
NICNAS. 2001. Tetrachloroethylene. Priority existing chemical assessment report. No. 15. National Industrial Chemicals Notification and Assessment Scheme.
NIOSH. 1980. Teratogenic-mutagenic risk of workplace contaminants: Trichloroethylene, perchloroethylene, and carbon disulfide. Report to National Institute for Occupational Safety and Health, Cincinnati, OH by Litton Bionetics, Inc., Kensington, MD. Publication no. 82-185075.
NIOSH. 1994. NIOSH manual of analytical methods. Third edition. Second supplement. Cincinnati, OH: NIOSH, U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health, NIOSH method no. 1003.
NIOSH. 2013. Tetrachloroethylene. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/. April 24, 2013.
NOES. 1990. National Occupational Exposure Survey (1981-1983). Cincinnati, OH: U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health.
NRC. 1993. Pesticides in the diets of infants and children. Washington, DC. National Research Council.
NRC. 2010. Review of the Environmental Protection Agency’s draft IRIS assessment of tetrachloroethylene. Washington, DC: National Research Council of the National Academies. 68–74, 81–113. http://www.nap.edu/catalog.php?record_id=12863. October 14, 2014.
NTP. 1986. Toxicology and carcinogenesis studies of tetrachloroethylene (perchloroethylene) (CAS No. 127-18-4) in F344/N rats and B6C3F_1_ mice (inhalation studies). National Toxicology Program-technical report series no. 311. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. NIH publication no. 86-2567.
NTP. 2016. Report on carcinogens. 14th edition. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html. May 30, 2018.
NYSDH. 2006. Final. Guidance for evaluating soil vapor intrusion in the state of New York. New York State Department of Health. http://www.health.ny.gov/environmental/investigations/soil_gas/svi_guidance/docs/svi_main.pdf. August 28, 2013.
*Oddone E, Edefonti V, Scaburri A, . 2014. Female breast cancer and electrical manufacturing: Results of a nested case-control study. J Occup Health 56(5):369–378.25168925
Odum J, Green T, Foster JR, . 1988. The role of trichloroacetic acid and peroxisome proliferation in the differences in carcinogenicity of perchloroethylene in the mouse and rat. Toxicol Appl Pharmacol 92:103–112.3341020
Ogata M, Takasuka Y, Tomokuni K, . 1971. Excretion of organic chlorine compounds in the urine of persons exposed to vapours of trichloroethylene and tetrachloroethylene. Br J Ind Med 28:386–390.5124840
OHM/TADS. 1990. Tetrachloroethylene. Oil and Hazardous Materials/Technical Assistance Data System, Chemical Information System.
Ohtsuki T, Sato K, Koizumi A, . 1983. Limited capacity of humans to metabolize tetrachloroethylene. Int Arch Occup Environ Health 51:381–390.6862652
*Ojajarvi A, Partanen T, Ahlbom A, . 2001. Risk of pancreatic cancer in workers exposed to chlorinated hydrocarbon solvents and related compounds: A meta-analysis. Am J Epidemiol 153(9):841–850.11323314
*Ojajarvi A, Partanen T, Ahlbom A, . 2007. Estimating the relative risk of pancreatic cancer associated with exposure agents in job title data in a hierarchical Bayesian meta-analysis. Scand J Work Environ Health 33(5):325–335.17973058
Okouchi S. 1986. Volatilization coefficient for stripping trichloroethylene, 1,1,1-trichloroethylene, and tetrachloroethylene from water. Water Sci Technol 181:137–138.
*Olsen GW, Heam S, Cook RR, . 1989. Mortality experience of a cohort of Louisiana USA chemical workers. J Occup Med 31:32–34.2738748
Olsen J, Hemminki K, Ahlborg G, . 1990. Low birthweight, congenital malformations, and spontaneous abortions among dry cleaning workers in Scandinavia. Scand J Work Environ Health 16:163–168.2143312
Olson MJ, Johnson JT, Reidy CA. 1990. A comparison of male rat and human urinary proteins: Implications for human resistance to hyaline droplet nephropathy. Toxicol Appl Pharmacol 102:524–536.1690459
Onofrj M, Thomas A, Paci C, . 1999. Optic neuritis with residual tunnel vision in perchloroethylene toxicity. Eur Neurol 41(1):51–53.9885330
Opdam JJG, Smolders JFJ. 1986. Alveolar sampling and fast kinetics of tetrachloroethene in man. I. Alveolar sampling. Br J Ind Med 43:814–824.3801333
Oppelt ET. 1987. Incineration of hazardous waste. A critical review. J Air Pollut Control Assoc 37:558–586.
OSHA. 2005. Reducing worker exposure to perchloroethylene (PERC) in dry cleaning. U.S. Department of Labor, Occupational Safety and Health Administration.
OSHA. 2013a. List of highly hazardous chemicals, toxics, and reactives. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations 29 CFR 1910.119, Appendix A. http://www.osha.gov/law-regs.html. April 24, 2013.
OSHA. 2013b. Toxic and hazardous substances. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations 29 CFR 1910.1000, Table Z-2. http://www.osha.gov/law-regs.html. April 24, 2013.
Oshiro WM, Krantz QT, Bushnell PJ. 2008. Characterization of the effects of inhaled perchloroethylene on sustained attention in rats performing a visual signal detection task. Neurotoxicol Teratol 30(3):167–174.18299185
Otson R, Williams DT. 1982. Headspace chromatographic determination of water pollutants. Anal Chem 54:942–946.
Otson R, Williams DT, Bothwell PD. 1982. Volatile organic compounds in water at thirty Canadian potable water treatment facilities. J Assoc Off Anal Chem 65:1370–1374.
Otto D, Hudnell K, Boyes W. 1988. Electrophysiological measures of visual and auditory function as indices of neurotoxicity. Toxicology 49:205–218.3287694
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
*Palmer RB, Phillips SD. 2007. Chlorinated hydrocarbons. In: Shannon MW, Borron SW, Burns MJ, eds. Haddad and Winchester’s clinical management of poisoning and drug overdose. 4th ed. Philadelphia PA: Saunders Elsevier, 1347–1361.
Pankow JF, Rosen ME. 1988. Determination of volatile compounds in water by purging directly to a capillary column with whole column cryotrapping. Environ Sci Technol 22:398–405.
Park KS, Sorenson DL, Sims JL. 1988. Volatilization of wastewater trace organics in slow rate land treatment systems. Hazard Waste Hazard Mater 5:219–229.
Parsons F, Barrio-Lage G, Rice R. 1985. Biotransformation of chlorinated organic solvents in static microcosms. Environ Toxicol Chem 4:739–742.
Parsons F, Wood PR, Demarco J. 1984. Transformation of tetrachloroethene and trichloroethene in microcosms and groundwater. J Am Water Works Assoc 76:56–59.
Patel R, Janakiraman N, Johnson R, . 1973. Pulmonary edema and coma from perchloroethylene. J Am Med Assoc 223:1510.
Paulu C, Aschengrau A, Ozonoff D. 1999. Tetrachloroethylene-contaminated drinking water in Massachusetts and the risk of colon-rectum, lung, and other cancers. Environ Health Perspect 107(4):265–271.10090704
Pearson CR, McConnell G. 1975. Chlorinated Cl and C2 hydrocarbons in the marine environment. Proc R Sot Lond [Biol] 189:305–332.
Peers AM. 1985. Method 5: Determination of trichloroethylene and tetrachloroethylene in air. IARC Sci Publ 68:205–211.
Pegg DG, Zempel JA, Braun WH, . 1979. Disposition of (^14^C) tetrachloroethylene following oral and inhalation exposure in rats. Toxicol Appl Pharmacol 51:465–474.538758
Pekari K, Aitio A. 1985a. Method 29: Determination of trichloroacetic acid in urine. International Agency for Research on Cancer Science Publication 68:467–472.
Pekari K, Aitio A. 1985b. Method 30: Determination of 2,2,2-trichloroethanol in urine. International Agency for Research on Cancer Science Publication 68:473–478.
Pellizzari ED, Hartwell TD, Harris BS, . 1982. Purgeable organic compounds in mother’s milk. Bull Environ Contam Toxicol 28:322–328.7082873
Pennell KD, Jin M, Abriola LM, . 1994. Surfactant enhanced remediation of soil columns contaminated by residual tetrachloroethylene. J Contam Hydrol 16:35–53.
Pennell KG, Bozkurt O, Suuberg EM. 2009. Development and application of a three-dimensional finite element vapor intrusion model. J Air Waste Manage Assoc 59(4):447–460.
Pennell KG, Scammell MK, McClean MD, . 2013. Sewer gas: An indoor air source of PCE to consider during vapor intrusion investigations. Ground Water Monit Remed 33(3):119–126.
Perrin MC, Opler MG, Harlap S, . 2007. Tetrachloroethylene exposure and risk of schizophrenia: Offspring of dry cleaners in a population birth cohort, preliminary findings. Schizophr Res 90(1–3):251–254.17113267
Pesch B, Haerting J, Ranft U, . 2000a. Occupational risk factors for renal cell carcinoma: Agent-specific results from a case-control study in Germany. Int J Epidemiol 29:1014–1024.11101542
Pesch B, Haerting J, Ranft U, . 2000b. Occupational risk factors for urotheliial carcinoma: Agent-specific results from a case-control study in Germany. Int J Epidemiol 29:238–247. 10.1093/ije/29.2.238.
*Pezzoli G, Cereda E. 2013. Exposure to pesticides or solvents and risk of Parkinson disease. Neurology 80(22):2035–2041. 10.1212/WNL.0b013e318294b3c8.23713084
Pezzagno G, Imbriani M, Ghittori S, . 1988. Urinary concentration, environmental concentration, and respiratory uptake of some solvents: Effect of the work load. Am Ind Hyg Assoc J 49:546–552.3195471
Philip BK, Mumtaz MM, Latendresse JR, . 2007. Impact of repeated exposure on toxicity of perchloroethylene in Swiss Webster mice. Toxicology 232(1–2):1–14.17267091
Piet GJ, Morra CHF, DeKruijf HAM. 1981. The behavior of organic micropollutants during passage through the soil. Quality of Groundwater, Proceedings of an International Symposium. Stud Environ Sci 17:557–564.
Piper WN, Sparschu GL. 1969. A comparison of the inhalation toxicity of 1,1,1,2-tetrachloroethane and perchloroethylene in the rat. Dow Chemical. Submitted to the U.S. Environmental Protection Agency under TSCA, Section 8d. OTS0515971.
Pocklington DW. 1992. Determination of tetrachloroethylene. Results of a collaborative study and the standardized method. J Am Oil Chem Soc 69(8):789–793.
Poet TS, Weitz KK, Gies RA, . 2002. PBPK modeling of the percutaneous absorption of perchloroethylene from a soil matrix in rats and humans. Toxicol Sci 67(1):17–31.11961212
Polder MD, Hulzebos EM, Jager DT. 1998. Bioconcentration of gaseous organic chemicals in plant leaves: Comparison of experimental data with model predictions. Environ Toxicol Chem 17(5):962–968.
Poli D, Manini P, Andreoli R, . 2005. Determination of dichloromethane, trichloroethylene and perchloroethylene in urine samples by headspace solid phase microextraction gas chromatography-mass spectrometry. J Chromatogr B Analyt Technol Biomed Life Sci 820(1):95–102.
Popp W, Muller G, Baltes-Schmitz B, . 1992. Concentrations of tetrachloroethene in blood and trichloroacetic acid in urine of workers and neighbors of dry cleaning shops. Int Arch Occup Environ Health 63:393–395.1544687
Potter CL, Chang LW, Deangelo AB, . 1996. Effects of four trihalomethanes on DNA strand breaks, renal hyaline droplet formation and serum testosterone in male F-344 rats. Cancer Lett 106(2):235–242.8844978
Prentice, RL. 1986. Comment. J Am Stat Assoc 81(395):600–601.
Price PJ, Hassett CM, Mansfield JI. 1978. Transforming activities of trichloroethylene -and proposed industrial alternatives. In Vitro 14:290–293.669729
Price RG, Taylor SA, Crutcher E, . 1995. The assay of laminin fragments in serum and urine as an indicator of renal damage induced by toxins. Toxicol Lett 77:313–318.7618157
Pukkala E, Martinsen JI, Lynge E, . 2009. Occupation and cancer - follow-up of 15 million people in five Nordic countries. Acta Oncol 48(5):646–790. 10.1080/02841860902913546.19925375
Purdue MP, Stewart PA, Friesen MC, . 2017. Occupational exposure to chlorinated solvents and kidney cancer: A case-control study. Occup Environ Med 74(4):268–274. 10.1136/oemed-2016-103849.27803178
Radican L, Blair A, Stewart P, . 2008. Mortality of aircraft maintenance workers exposed to trichloroethylene and other hydrocarbons and chemicals: Extended follow-up. J Occup Environ Hyg 50:1306–1319.
Radican L, Wartenberg D, Rhoads GG, . 2006. A retrospective occupational cohort study of end-stage renal disease in aircraft workers exposed to trichloroethylene and other hydrocarbons. J Occup Environ Med 48(Jan):1–12.16404204
Raisanen J, Niemela R, Rosenberg C. 2001. Tetrachloroethylene emissions and exposure in dry cleaning. J Air Waste Manag Assoc 51(12):1671–1675.15666472
Rajamanikandan S, Sindhu T, Durgapriya D, . 2012. Protective effect of Mollugo nudicaulis Lam. on acute liver injury induced by perchloroethylene in experimental rats. Asian Pac J Trop Med 5(11):862–867.23146799
Rampy LW, Quast JF, Balmer MF, . 1978. Results of a long-term inhalation toxicity study on rats of a perchloroethylene (tetrachloroethylene) formulation. Dow Chemical. Submitted to the U.S. Environmental Protection Agency under TSCA, Section 8d. OTS0515968.
Ramsey JD, Flanagan RJ. 1982. Detection and identification of volatile organic compounds in blood by headspace gas chromatography as an aide to the diagnosis of solvent abuse. J Chromatogr 240:423–444.7096519
Rao HV, Brown DR. 1993. A physiologically based pharmacokinetic assessment of tetrachloroethylene in groundwater for a bathing and showering determination. Risk Anal 13(1):37–49.8451459
Rao VR, Levy K, Lustik M. 1993. Logistic regression of inhalation toxicities of perchloroethylene-Application in noncancer risk assessment. Regul Toxicol Pharmacol 18:233–247.8278644
Rasmussen RA, Harsch DE, Sweany PH, . 1977. Determination of atmospheric halocarbons by a temperature-programmed gas chromatographic freezeout concentration method. J Air Pollut Control Assoc 27:579–581.
Rastkari N, Yunesian M, Ahmadkhaniha R. 2011. Exposure assessment to trichloroethylene and perchloroethylene for workers in the dry cleaning industry. Bull Environ Contam Toxicol 86(4):363–367.21416139
*Ratnoff WD, Gress RE. 1980. The familial occurrence of polycythemia vera: Report of a father and a son, with consideration of the possible etiologic role of exposure to organic solvents, including tetrachloroethylene. Blood 56:233–236.7397379
Rea WJ, Pan Y, Laseter JL, . 1987. Toxic volatile organic hydrocarbons in chemically sensitive patients. Clin Ecol 5:70–74.
Reinhardt CF, Mullin LS, Maxfield ME. 1973. Epinephrine-induced cardiac arrhythmia potential of some common industrial solvents. J Occup Med 15:953–955.4763670
Reitz, RH, Gargas ML, Mendrala AL, . 1996. In vivo and in vitro studies of perchloroethylene metabolism for physiologically based pharmacokinetic modeling in rats, mice, and humans. Toxicol Appl Phamacol 136:289–306.
RePORTER. 2013. Tetrachloroethylene. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. August 28, 2013.
RePORTER. 2018. Tetrachloroethylene. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. September 6, 2018.
Riihimaki V, Pfaffli, P. 1978. Percutaneous absorption of solvent vapors in man. Scand J Work Environ Health 4:73–85.644269
Robb EV, McGaughey JF, Sykes AL, . 1986. Recovery of principal organic hazardous constituents and products of incomplete combustion from a volatile organic sampling train. Research Triangle Park, NC: U.S. Environmental Protection Agency, Air and Energy Engineering Research Lab. EPAf6007861025.
Roberts PV, Dandliker PG. 1983. Mass transfer of volatile organic contaminants from aqueous solution to the atmosphere during surface aeration. Environ Sci Technol 17:484–489.22283168
Roberts PV, Goltz MN, Mackay DM. 1986. A natural gradient experiment on solute transport in a sand aquifer. 3. Retardation estimates and mass balance for organic solutes. Water Resour Res 22(13):2047–2058.
Roda C, Kousignian I, Ramond A, . 2013. Indoor tetrachloroethylene levels and determinants in Paris dwellings. Environ Res 120:1–6.23127492
Rodriguez CE, Mahle DA, Gearhart JM, . 2007. Predicting age-appropriate pharmacokinetics of six volatile organic compounds in the rat utilizing physiologically based pharmacokinetic modeling. Toxicol Sci 98(1):43–56.17426107
Rogan WJ. 1986. Comment. J Am Stat Assoc 81(395):602–603.
Rosengren LE, Kjellstrand P, Haglid KG. 1986. Tetrachloroethylene: Levels of DNA and S-100 in the gerbil CNS after chronic exposure. Neurobehav Toxicol Teratol 8:201–206.3713968
Rowe BL, Toccalino PL, Moran MJ, . 2007. Occurrence and potential human-health relevance of volatile organic compounds in drinking water from domestic wells in the United States. Environ Health Perspect 115(11):1539–1546.18007981
Rowe VK, McCollister DD, Spencer HC, . 1952. Vapor toxicity of tetrachloroethylene for laboratory animals and human subjects. AMA Arch Ind Hyg Occup Med 5:566–579.14922990
Ruckart PZ, Bove FJ, Maslia M. 2013. Evaluation of exposure to contaminated drinking water and specific birth defects and childhood cancers at Marine Corps Base Camp Lejeune, North Carolina: A case-control study. Environ Health 12(104):10.1186. 10.1186/1476-069X-12-104.23351724
Ruckart PZ, Bove FJ, Maslia M. 2014. Evaluation of contaminated drinking water and preterm birth, small for gestational age, and birth weight at Marine Corps Base Camp Lejeune, North Carolina: A cross-sectional study. Environ Health 13:99. 10.1186/1476-069x-13-99.25413571
Ruckart PZ, Bove FJ, Shanley E, 3rd, . 2015. Evaluation of contaminated drinking water and male breast cancer at Marine Corps Base Camp Lejeune, North Carolina: A case control study. Environ Health 14:74. 10.1186/s12940-015-0061-4.26376727
Ruder AM, Ward EM, Brown DP. 1994. Cancer mortality and female and male dry cleaning workers. J Occup Environ Med 36(8):867–874.
Ruder AM, Ward EM, Brown DP. 2001. Mortality in dry-cleaning workers: An update. Am J Ind Med 39(2):121–132.11170155
Ruder AM, Yiin JH, Waters MA, . 2013. The Upper Midwest Health Study: Gliomas and occupational exposure to chlorinated solvents. Occup Environ Med 70(2):73–80. 10.1136/oemed-2011-100588.23104734
Ruiz P, Ray M, Fisher J, . 2011. Development of a human physiologically based pharmacokinetic (PBPK) toolkit for environmental pollutants. Int J Mol Sci 12:7469–7480. 10.3390/ijms12117469.
Rutkiewicz I, Jakubowska N, Polkowska Z, . 2011. Monitoring of Occupational Exposure to volatile organohalogen solvents (VOXs) in human urine samples of dry-cleaner workers by TLHS-DAI-GC-ECD procedure. Ind Health 49(1):126–132.20823626
Ryoo D, Shim H. 2000. Aerobic degradation of tetrachloroethylene by toluene-o-xylene monooxygenase of Pseudomonas stutzeri OX1. Nat Biotechnol 18(7):775–778.10888848
Sack TM, Steele DH, Hammerstrom K, . 1992. A survey of household products for volatile organic compounds. Atmos Environ 26(6):1063–1070.
Saisho. 1994. Bioaccumulation of volatile chlorinated hydrocarbons in blue mussel, Mytilus edulus, and killfish, Oryzias latipes. Jpn J Toxicol Environ Health 40:274–278.
Saland G. 1967. Accidental exposure to perchloroethylene. N Y State J Med 67:2359–2361.5234050
Sallmén M, Lindbohm ML, Anttila A, . 1998. Time to pregnancy among the wives of men exposed to organic solvents. Occup Environ Med 55(1):24–30.9536159
Sallmén M, Lindbohm ML, Kyyronen P, . 1995. Reduced fertility among women exposed to organic solvents. Am J Ind Med 27:699–713.7611306
Sandground JH. 1941. Coma following medication with tetrachloroethylene. J Am Med Assoc 117:440–441.
*Santibanez M, Vioque J, Alguacil J, . 2008. Occupational exposures and risk of oesophageal cancer by histological type: A case-control study in eastern Spain. Occup Environ Med 65(11):774–781.18614460
Sarangapani R, Gentry PR, Covington TR, . 2003. Evaluation of the potential impact of age- and gender-specific lung morphology and ventilation rate on the dosimetry of vapors. Inhal Toxicol 15(10):987–1016.12928976
Saunders NR, Ek CJ, Habgood MD, . 2008. Barriers in the brain: A renaissance? Trends Neurosci 31(6):279–286. 10.1016/j.tins.2008.03.003.18471905
Saunders NR, Liddelow SA, Dziegielewska KM. 2012. Barrier mechanisms in the developing brain. Front Pharmacol 3:46. 10.3389/fphar.2012.00046.22479246
Savolainen H, Pfaffli P, Tengen M, . 1977. Biochemical and behavioral effects of inhalation exposure to tetrachloroethylene and dichloromethane. J Neuropathol Exp Neurol 36:941–949.925719
Scheuplein R, Charnley G, Dourson M. 2002. Differential sensitivity of children and adults to chemical toxicity. I. Biological basis. Regul Toxicol Pharmacol 35(3):429–447.12202057
Schlichting LM, Wright PFA, Stacey NH. 1992. Effects of tetrachloroethylene on hepatic and splenic lymphocytoxic activities in rodents. Toxicol Ind Health 8(5):255–266.1455436
Schreiber JS. 1993. Predicted infant exposure to tetrachloroethylene in human breast milk. Risk Anal 13(5):515–524.8259441
Schreiber JS, House S, Prohonic E, . 1993. An investigation of indoor air contamination in residences above dry cleaners. Risk Anal 13(3):335–344.8341809
Schreiber JS, Hudnell HK, Geller AM, . 2002. Apartment residents’ and day care workers’ exposures to tetrachloroethylene and deficits in visual contrast sensitivity. Environ Health Perspect 110(7):655–664.
Schroers HJ, Jermann E, Begerow J, . 1998. Determination of physiological levels of volatile organic compounds in blood using static headspace capillary gas chromatography with serial triple detection. Analyst 123(4):715–720.9684406
Schultz B, Kjeldsen P. 1986. Screening of organic matter in leachates from sanitary landfills using gas chromatography combined with mass spectrometry. Water Res 20:965–970.
Schumann AM, Quast JF, Watanabe PG. 1980. The pharmacokinetics and macromolecular interactions of perchloroethylene in mice and rats as related to oncogenicity. Toxicol Appl Pharmacol 55:207–219.7423514
Schwarzenbach RP, Giger W, Hoehn E, Schneider JK. 1983. Behavior of organic compounds during infiltration of river water to ground water. Field studies. Environ Sci Technol 17:472–479.22283166
Schwarzenbach RP, Molnar-Kubica E, Giger W, . 1979. Distribution, residence time, and fluxes of tetrachloroethylene and 1,4-dichlorobenzene in Lake Zurich, Switzerland. Environ Sci Technol 13:1367–1373.
Schwetz BA, Leong BKJ, Gehring PJ. 1975. The effect of maternally inhaled trichloroethylene, perchloroethylene, methyl chloroform, and methylene chloride on embryonal and fetal development in mice and rats. Toxicol Appl Pharmacol 32:84–96.1135881
Seeber A. 1989. Neurobehavioral toxicity of long-term exposure to tetrachloroethylene. Neurotoxicol Teratol 11:579–583.2626148
Seidel HJ, Weber L, Barthel E. 1992. Hematological toxicity of tetrachloroethylene in mice. Arch Toxicol 66:228–230.1497490
*Seidler A, Mohner M, Berger J, . 2007. Solvent exposure and malignant lymphoma: A population-based case-control study in Germany. J Occup Med Toxicol 2:2. 10.1186/1745-6673-2-2.17407545
Seiji K, Inoue O, Jin C, . 1989. Dose-excretion relationship in tetrachloroethylene-exposed workers and the effect of tetrachloroethylene co-exposure on trichloroethylene metabolism. Am J Ind Med 16:675–684.2596489
Seiji K, Jin C, Watanabe T, . 1990. Sister chromatid exchanges in peripheral lymphocytes of workers exposed to benzene, trichloroethylene, or tetrachloroethylene, with references to smoking habits. Int Arch Occup Environ Health 62:171–176.2323835
Seip HM, Alstad J, Carlberg GE, . 1986. Measurement of mobility of organic compounds in soils. Sci Total Environ 50:87–101.
Selden AI, Ahlborg G, Jr. 2011. Cancer morbidity in Swedish dry-cleaners and laundry workers: Historically prospective cohort study. Int Arch Occup Environ Health 84(4):435–443.20886350
Seo M, Ikeda K, Okamura T, . 2008b. Enhancing effect of chlorinated organic solvents on histamine release and inflammatory mediator production. Toxicology 243(1–2):75–83.18006135
Seo M, Yamagiwa T, Kobayashi R, . 2008a. A small amount of tetrachloroethylene ingestions from drinking water accelerates antigen-stimulated allergic responses. Immunobiology 213(8):663–669.18950594
Seo M, Kobayashi R, Okamura T, . 2012. Enhancing effects of trichloroethylene and tetrachloroethylene on type I allergic responses in mice. J Toxicol Sci 37(2):439–445.22467035
Sexton K, Adgate JL, Church TR, . 2005. Children’s exposure to volatile organic compounds as determined by longitudinal measurements in blood. Environ Health Perspect 113(3):342–349.15743726
Shafer TJ, Bushnell PJ, Benignus VA, . 2005. Perturbation of voltage-sensitive Ca2+ channel function by volatile organic solvents. J Pharmacol Exp Ther 315(3):1109–1118.16109744
Sharanjeet-Kaur (no initial), Mursyid A, Kamaruddin A, . 2004. Effect of petroleum derivatives and solvents on colour perception. Clin Exp Optom 87(4–5):339–343.15312037
Sharma PK, McCarty PL. 1996. Isolation and characterization of a facultatively aerobic bacterium that reductively dehalogenates tetrachloroethene to cis-1,2-dichloroethene. Appl Environ Microbiol 62(3):761–765.16535267
Shigetoshi Y, Nagahito M, Tomomichi M, . 1993. European patent application. Process for the manufacture of tetrachloroethylene. Application number 93109052.6.
Shimada T, Swanson A, Leber P, . 1983. The evaluation for genotoxicity of several halogenated solvents. Environ Mutagen 5:447.
Shusterman D. 2018. Trichloroethane, trichloroethylene, and tetrachloroethylene. In: Olson KR, Anderson IB, Benowitz NL, . eds. Poisoning and drug overdose. 7th ed. McGraw-Hill Education.
Silver SR, Pinkerton LE, Fleming DA, . 2014. Retrospective cohort study of a microelectronics and business machine facility. Am J Ind Med 57(4):412–424. 10.1002/ajim.22288.24375784
Singh HB, Lillian D, Appleby A, . 1975. Atmospheric formation of carbon tetrachloride from tetrachloroethylene. Environ Lett 10:253–256.1213012
Singh HB, Salas LJ, Stiles RE. 1982. Distribution of selected gaseous organic mutagens and suspect carcinogens in ambient air. Environ Sci Technol 16:872–880.22236265
Skender L, Karacic V, Bosner B, . 1993. Assessment of exposure to trichloroethylene and tetrachloroethylene in the population of Zagreb, Croatia. Int Arch Occup Environ Health 65:S163–S165.8406918
Skender L, Karacic V, Bosner B, . 1994. Assessment of urban population exposure to trichloroethylene and tetrachloroethylene by means of biological monitoring. Arch Environ Health 49(6):445–451.7818286
Skender LJ, Karacic V, Prpic-Majic D. 1991. A comparative study of human levels of trichloroethylene and tetrachloroethylene after occupational exposure. Arch Environ Health 46(3):174–178.2039273
*Smith EM, Miller ER, Woolson RF, . 1985. Bladder cancer risk among laundry workers, dry cleaners, and others in chemically related occupations. J Occup Med 27:295–297.3998883
Solet D, Robins TG. 1991. Renal function in dry cleaning workers exposed to perchloroethylene. Am J Ind Med 20:601–614.1793103
Solet D, Robins TG, Sampaio C. 1990. Perchloroethylene exposure assessment among dry cleaning workers. Am Ind Hyg Assoc J 51(10):566–574.2251984
Soni M, Nomiyama H, Nomiyama K. 1990. Chronic inhalation effects of tetrachloroethylene on hepatic and renal microsomal electron transport components and δ-aminolevulinic acid dehydratase in rats. Toxicol Lett 54:207–213.2124380
Sonnenfeld N, Hertz-Picciotto I, Kaye WE. 2001. Tetrachloroethylene in drinking water and birth outcomes at the US Marine Corps Base at Camp Lejeune, North Carolina. Am J Epidemiol 154(10):902–908.11700244
Spearow JL, Gettmann K, Wade M. 2017. Review: Risk assessment implications of variation in susceptibility to perchloroethylene due to genetic diversity, ethnicity, age, gender, diet and pharmaceuticals. Hum Ecol Risk Assess 23(6):1466–1492.
Spencer AB, Earnest GS, Kovein RJ. 1995. In-depth survey report: Exposures during the spotting procedure in a commercial dry cleaner at Widmer’s Dry Cleaning, Cincinnati, Ohio. U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control and Prevention, National Institute for Occupational Safety and Health. Report No. ECTB 201-13b.
Spicer CW, Holdren MW, Slivon LE, . 1986. Intercomparison of sampling techniques for toxic organic compounds in indoor air. Proceedings of the 1986 EPA/APCA Symposium on Measurement of Toxic Air Pollutants, Raleigh, NC, April 27-30, 1986, Environmental Monitoring Systems Laboratory, U.S. Environmental Protection Agency, EPA600986013, 45–60.
Spirtas R, Stewart PA, Lee JS, . 1991. Retrospective cohort mortality study of workers at an aircraft maintenance facility. I. Epidemiological results. Br J Ind Med 48(8):515–530.1878308
SRI. 2011. 2011 Directory of chemical producers United States. In: 2011 Directory of chemical producers United States. SRI Consulting, 744–745.
*Stemhagen A, Slade J, Altman R . 1983. Occupational risk factors and liver cancer: A retrospective case-control study of primary liver cancer in New Jersey. Am J Epidemiol 117:443–454.6837558
Stewart RD. 1969. Acute tetrachloroethylene intoxication. J Am Med Assoc 208:1490–1492.
Stewart RD, Dodd HC. 1964. Absorption of carbon tetrachloride, trichloroethylene, tetrachloroethylene, methylene chloride, and 1,1,1-trichloroethane through the human skin. Am Ind Hyg Assoc J 25:439–446.14209666
Stewart RD, Baretta ED, Dodd HC, . 1970. Experimental human exposure to tetrachloroethylene. Arch Environ Health 20:224–229.
Stewart RD, Erley DS, Schaffer AW, . 1961a. Accidental vapor exposure to anesthetic concentrations of a solvent containing tetrachloroethylene. Ind Med Surg 30:327–330.
Stewart RD, Gay HH, Erley DS, . 1961b. Human exposure to tetrachloroethylene vapor: Relationship of expired air and blood concentrations to exposure and toxicity. Arch Environ Health 2:516–522.
Stewart RD, Hake CL, Forster HV, . 1981. Tetrachloroethylene: Development of a biologic standard for the industrial worker by breath analysis. Cincinnati, OH: National Institute for Occupational Safety and Health. Contract no. HSM 99-72-84. NIOSH-MCOW-ENVM-PCE-74-6. PB82152166.
Stewart RD, Hake CL, Wu A, . 1977. Effects of perchloroethylene/drug interaction on behavior and neurological function. Final report. Washington, DC: National Institute for Occupational Safety and Health. PB83174607.
Storm JE, Mazor KA, Aldous KM, . 2011. Visual contrast sensitivity in children exposed to tetrachloroethylene. Arch Environ Occup Health 66(3):166–177.21864105
Storm JE, Mazor KA, Shost SJ, . 2013. Socioeconomic disparities in indoor air, breath, and blood perchloroethylene level among adult and child residents of buildings with or without a dry cleaner. Environ Res 122:88–97.23453848
Story DL, Meierhenry EF, Tyson CA, . 1986. Differences in rat liver enzyme-altered foci produced by chlorinated aliphatics and phenobarbital. Toxicol Ind Health 2:351–362.3296316
Stroo HF, Leeson A, Marqusee JA, . 2012. Chlorinated ethene source remediation: Lessons learned. Environ Sci Technol 46(12):6438–6447.22558915
Struwe M, Zeller A, Singer T, . 2011. Possibility of methodical bias in analysis of comet assay studies: Re: DNA damage detected by the alkaline comet assay in the liver of mice after oral administration of tetrachloroethylene. Mutagenesis 25:133–138.
*Stutz DR, Ulin S. 1992. Hazardous materials injuries: A handbook for pre-hospital care. Third edition. Beltsville, MD: Bradford Communications Corporations, 286–287.
Su C, Goldberg ED. 1976. Environmental concentration and fluxes of some halocarbons. In: Windom HL, Duce, KA, eds. Marine pollutant transfer. Lexington MA, 353–374.
Suber RL. 1989. Clinical pathology for toxicologists. In: Hayes AW, ed. Principles and methods of toxicology. 2nd ed. New York, NY: Raven Press, 485–519.
Sullivan DA, Jones AD, Williams JG. 1985. Results of the U.S. Environmental Protection Agency’s air toxics analysis in Philadelphia. In: Proceedings of the 78th Annual Meeting of the Air Pollution Control Association. Vol. 2, 1–15.
Suzaki H, Aoki A, Nomura Y. 1997. Regeneration of olfactory mucosa in mice after inhalation exposure to perchloroethylene. J Otorhinolaryngol Relat Spec 59(2):91–96.
Swan SH, Robins JM. 1986. Comment. J Am Stat Assoc 81(395):604–609.
Swann RL, Laskowski DA, McCall PJ, . 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Res Rev 85:17–28.
Swenberg JA, Short B, Borghoff S, . 1989. The comparative pathobiology of a α2μ-globulin nephropathy. Toxicol Appl Pharmacol 97:35–46.2464861
Szakmary E, Ungvary G, Tatrai E. 1997. The offspring-damaging effect of tetrachloroethylene in rats, mice and rabbits. Cent Eur J Occup Environ Med 3(1):33–39.
Tabak HH, Quave SA, Mashni CI, . 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53:1503–1518.
Talibov M, Auvinen A, Weiderpass E, . 2017. Occupational solvent exposure and adult chronic lymphocytic leukemia: No risk in a population-based case-control study in four Nordic countries. Int J Cancer 141(6):1140–1147. 10.1002/ijc.30814.28571111
Tanios MA, El Gamal H, Rosenberg BJ, . 2004. Can we still miss tetrachloroethylene-induced lung disease? The emperor returns in new clothes. Respiration 71(6):642–645.15627878
Taskinen H, Anttila A, Lindbohm ML, . 1989. Spontaneous abortions and congenital malformations among the wives of men occupationally exposed to organic solvents. Scand J Work Environ Health 15:345–352.2799322
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton NJ: Princeton Scientific Publishing, 365–394.
Thomas RG. 1982. Volatilization from water. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods: Environmental behavior of organic compounds. New York, NY: McGraw-Hill, 1–2, 13, 25.
Thompson KM, Evans JS. 1993. Workers’ breath as a source of perchloroethylene (pert) in the home. J Expo Anal Environ Epidemiol 3(4):417–430.8173342
Tichenor BA, Sparks LE, Jackson MD, . 1990. Emissions of perchloroethylene from dry cleaned fabrics. Atmos Environ 24A(5):1219–1229.
Till C, Rovet JF, Koren G, . 2003. Assessment of visual functions following prenatal exposure to organic solvents. Neurotoxicology 24(4–5):725–731.12900086
Tinston DJ. 1995. Perchloroethylene: Multigeneration inhalation study in the rat. Report No: CTL/P/4097. Sponsored by Halogenated Solvents Industry Alliance, HSIA/90/0002.
‘t Mannetje A, De Roos AJ, Boffetta P, . 2016. Occupation and risk of non-Hodgkin lymphoma and its subtypes: A pooled analysis from the InterLymph Consortium. Environ Health Perspect 124(4):396–405. 10.1289/ehp.1409294.26340796
Toraason M, Butler MA, Ruder A, . 2003. Effect of perchloroethylene, smoking, and race on oxidative DNA damage in female dry cleaners. Mutat Res 539(1–2):9–18.12948810
Toraason M, Clark J, Dankovic D, . 1999. Oxidative stress and DNA damage in Fischer rats following acute exposure to trichloroethylene or perchloroethylene. Toxicology 138(1):43–53.10566590
TRI16. 2018. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: U.S. Environmental Protection Agency, Office of Information Analysis and Access. Office of Environmental Information. Toxics Release Inventory. http://www.epa.gov/triexplorer/. June 1, 2018.
Tsulaya VR, Bonashevskaya TI, Zykova VV, . 1977. [The toxicological characteristics of some chlorinated hydrocarbons]. Gig Sanit 8:50–53. (Russian)
Tsuruta H. 1975. Percutaneous absorption of organic solvents. (1) Comparative study of the in vivo percutaneous absorption of chlorinated solvents in mice. Ind Health 13:227–236.
Tsuruta H. 1977. Percutaneous absorption of organic solvents. (2) A method for measuring the penetration rate of chlorinated solvents through excised rat skin. Ind Health 15:131–139.
Tsuruta H. 1989. Skin absorption of organic solvent vapors in nude mice in vivo. Ind Health 27:37–47.2745160
Tu AS, Murray TA, Hatch KM, . 1985. In vitro transformation of BALB/C-3T3 cell by chlorinated ethanes and ethylenes. Cancer Lett 28:85–92.4027960
Tucker JD, Sorensen KJ, Ruder AM, . 2011. Cytogenetic analysis of an exposed-referent study: Perchloroethylene-exposed dry cleaners compared to unexposed laundry workers. Environ Health 10:16.21392400
Union Carbide. 1962. Comparative inhalation toxicities of perchloroethylene. Submitted to the U.S. Environmental Protection Agency under TSCA, Section 8d. OTS0515591.
Urano K, Murata C. 1985. Adsorption of principal chlorinated organic compounds on soil. Chemosphere 14:293–299.
USGS. 2003. Quality and sources of shallow ground water in areas of recent residential development in Salt Lake Valley, Salt Lake County, Utah. U.S. Geological Survey, U.S. Department of the Interior, National Water-Quality Assessment Program.
USGS. 2006. Volatile organic compounds in the nation’s ground water and drinking-water supply wells. United States Geological Survey, U.S. Department of the Interior, National Water-Quality Assessment Program.
USGS. 2012. Assessment of soil-gas contamination at three former fuel-dispensing sites, Fort Gordon, Georgia, 2010-2011. United States Geological Survey, U.S. Department of the Interior.
USITC. 2013. Tetrachloroethylene (Perchloroethylene) import and export data. United States International Trade Commission. http://www.usitc.gov. March 11, 2013.
Valencia R, Mason JM, Woodruff RC, . 1985. Chemical mutagenesis testing in Drosophila III. Results of 48 coded compounds tested for the National Toxicology Program. Environ Mutagen 7:325–348.3930234
Valic E, Waldhor T, Konnaris C, . 1997. Acquired dyschromatopsia in combined exposure to solvents and alcohol. Int Arch Occup Environ Health 70(6):403–406.9439987
Vamvakas S, Herkenhoff M, Dekant W, . 1989. Mutagenicity of tetrachloroethene in the Ames test: Metabolic activation by conjugation with glutathione. J Biochem Toxicol 4:21–27.2671372
*van der Mark M, Vermeulen R, Nijssen PC, . 2015. Occupational exposure to solvents, metals and welding fumes and risk of Parkinson’s disease. Parkinsonism Relat Disord 21(6):635–639. 10.1016/j.parkreldis.2015.03.025.25903042
Van Duuren BL, Goldschmidt BM, Loewengart G, . 1979. Carcinogenicity of halogenated olefinic and aliphatic hydrocarbons in mice. J Natl Cancer Inst 63:1433–1439.292813
Vartiainen T, Pukkala E, Rienoja T, . 1993. Population exposure to tri- and tetrachloroethene and cancer risk: Two cases of drinking water pollution. Chemosphere 27(7):1171–1181.
Vaughan TL, Stewart PA, Davis S, . 1997. Work in dry cleaning and the incidence of cancer of the oral cavity, larynx, and oesophagus. Occup Environ Med 54(9):692–695.9423585
Veith GD, Macek KJ, Petrocelli SR, . 1980. An evaluation of using partition coefficients and water solubility to estimate bioconcentration factors for organic chemicals in fish. In: Eaton JG, Parrish PR, Hendricks AC, eds. Aquatic Toxicology. Am Soc Test Mater ASTM STP 707, 116–129.
*Vemmer H, Rohleder K, Wieczoreck H, . 1984. [Perchloroethylene in the tissues of fattening pigs]. Landwirtsch Forsch 37:36–43. (German)
Verplanke AJ, Leummens MH, Herber RF. 1999. Occupational exposure to tetrachloroethene and its effects on the kidneys. J Occup Environ Med 41(1):11–16.9924715
Verschueren K. 1983. Handbook of environmental data on organic chemicals. New York, NY: Van Nostrand Reinhold, 1076–1080.
Viau C, Bernard A, Lauwerys R, . 1987. A cross-sectional survey of kidney function in refinery employees. Am J Ind Med 11:177–187.3493689
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238(2):476–483.8681961
Vieira V, Aschengrau A, Ozonoff D. 2005. Impact of tetrachloroethylene-contaminated drinking water on the risk of breast cancer: Using a dose model to assess exposure in a case-control study. Environ Health 4(1):3.15733317
Vingrys AJ, King-Smith PE. 1988. A quantitative scoring technique for panel tests of color vision. Invest Ophthalmol Vis Sci 29:50–63.3257208
Vizcaya D, Christensen KY, Lavoue J, . 2013. Risk of lung cancer associated with six types of chlorinated solvents: Results from two case-control studies in Montreal, Canada. Occup Environ Med 70(2):81–85. 10.1136/oemed-2012-101155.23104733
Vlaanderen J, Straif K, Pukkala E, . 2013. Occupational exposure to trichloroethylene and perchloroethylene and the risk of lymphoma, liver, and kidney cancer in four Nordic countries. Occup Environ Med 70(6):393–401. 10.1136/oemed-2012-101188.23447073
Vlaanderen J, Straif K, Ruder A, . 2014. Tetrachloroethylene exposure and bladder cancer risk: A meta-analysis of dry-cleaning-worker studies. Environ Health Perspect 122(7):661–666. 10.1289/ehp.1307055.24659585
Vogel TM, McCarty PL. 1985. Biotransformation of tetrachloroethylene to trichloroethylene, dichloroethylene, vinyl chloride and carbon dioxide under methanogenic conditions. Appl Environ Microbiol 49:1080–1083.3923927
Volkel W, Friedewald M, Lederer E, . 1998. Biotransformation of perchloroethene: Dosedependent excretion of trichloroacetic acid, dichloroacetic acid, and N-acetyl-S-(trichlorovinyl)-L-cystein in rats and humans after inhalation. Toxicol Appl Pharmacol 153(1):20–27.9875296
Volkel W, Pahler A, Dekant W. 1999. Gas chromatography-negative ion chemical ionization mass spectrometry as a powerful tool for the detection of mercapturic acids and DNA and protein adducts as biomarkers of exposure to halogenated olefins. J Chromatogr A 847(1–2):35–46.10431350
Voss JU, Roller M, Brinkmann E, . 2005. Nephrotoxicity of organic solvents: Biomarkers for early detection. Int Arch Occup Environ Health 78(6):475–485.15895243
Vroblesky DA. 1991. Mapping zones of contaminated ground-water discharge using creek-bottomsediment vapor samplers, Aberdeen Proving Ground, Maryland. Ground Water 29(1):7–12.
Vyskocil A, Emminger S, Tejral J. 1990. Study on kidney function in female workers exposed to perchloroethylene. Hum Exp Toxicol 9:377–380.2271228
Wakeham SG, Davis AC, Karas JL. 1983. Mesocosm experiments to determine the fate and persistence of volatile organic compounds in coastal seawater. Environ Sci Technol 17:611–617.22288706
Wall JM, Carreon RF. 1984. Perchloroethylene (99.97%) formulation: Acute toxicological properties. Dow Chemical. Submitted to the U.S. Environmental Protection Agency under TSCA, Section 8d. OTS0515966.
Wallace LA. 1986. Personal exposures, indoor and outdoor air concentrations and exhaled breath concentrations of selected volatile organic compounds measured for 600 residents of New Jersey, North Dakota, North Carolina, and California. Toxicol Environ Chem 12:215–236.
Wallace LA, Pellizzari ED, Hartwell TD, . 1986a. Concentrations of 20 volatile organic compounds in the air and drinking water of 350 residents of New Jersey compared with concentrations in their exhaled breath. J Occup Med 28:603–608.3746480
Wallace LA, Pellizzari ED, Hartwell TD, . 1986b. Results from the first three seasons of the TEAM study: Personal exposures, indoor-outdoor relationships, and breath levels of toxic air pollutants measured for 355 persons in New Jersey. In: Kopfler PC, Craun G, eds. Environmental epidemiology. Chelsea MI: Lewis Publishers, 181–200.
Wallace LA, Pellizzari ED, Hartwell TD. 1986c. Total exposure assessment methodology (TEAM) study: Personal exposures, indoor-outdoor relationships, and breath levels of volatile organic compounds in New Jersey. Environ Int 12:369–387.
Wallace LA, Pellizzari ED, Leaderer B, . 1987. Emissions of volatile organic compounds from building materials and consumer products. Atmos Environ 21:385–393.
Wallace LA, Pellizzari ED, Sheldon L, . 1986d. The total exposure assessment methodology (TEAM) study: Direct measurements of personal exposures through air and water for 600 residents of several U.S. cities. In: Cohen Y, ed. Pollutants in a multimedia environment. New York, NY: Plenum Publishing Corp., 289–315.
Walles SAS. 1986. Induction of single-strand breaks in DNA of mice by trichloroethylene and tetrachloroethylene. Toxicol Lett 31:31–35.3715914
*Wang G, Wang J, Ansari GAS, . 2017. Autoimmune potential of perchloroethylene: Role of lipid-derived aldehydes. Toxicol Appl Pharmacol 333:76–83. 10.1016/j.taap.2017.08.009.28818516
Wang JL, Chen WL, Tsai SY, . 2001. An in vitro model for evaluation of vaporous toxicity of trichloroethylene and tetrachloroethylene to CHO-K1 cells. Chem Biol Interact 137(2):139–154.11551530
Wang S, Karlsson JE, Kyrklund T, . 1993. Perchloroethylene-induced reduction in glial and neuronal cell marker proteins in rat brain. Pharmacol Toxicol 72:273–278.8372046
Ward RC, Travis CC, Hetrick DM, . 1988. Pharmacokinetics of tetrachloroethylene. Toxicol Appl Pharmacol 93:108–117.3353997
Warren DA, Reigle TG, Muralidhara S, . 1996. Schedule-controlled operant behavior of rats following oral administration of perchloroethylene: Time course and relationship to blood and brain solvent levels. J Toxicol Environ Health 47(4):345–362.8600288
Watanabe K, Sasaki T, Kawakami K. 1998. Comparisons of chemically-induced mutation among four bacterial strains, Salmonella typhimurium TA102 and TA2638, and Escherichia coli WP2/pKM101 and WP2 uvrA/pKM101: Collaborative study III and evaluation of the usefulness of these strains. Mutat Res 416(3):169–181.9729366
Wayne LG, Orcutt JA. 1960. The relative potentials of common organic solvents as precursors of eyeirritants in urban atmospheres. J Occup Med 2:383–388.13843215
Weant GE, McCormick GS. 1984. Nonindustrial sources of potentially toxic substances and their applicability to source apportionment methods. EPA450484003. PB84231232.
Webler T, Brown HS. 1993. Exposure to tetrachloroethylene via contaminated drinking water pipes in Massachusetts: A predictive model. Arch Environ Health 48(5):293–297.8215592
*Weiderpass E, Pukkala E, Vasama-Neuvonen K, . 2001. Occupational exposures and cancers of the endometrium and cervix uteri in Finland. Am J Ind Med 39(6):572–580.11385641
Wenzel DG, Gibson RD. 1951. A study of the toxicity and anthelminthic activity of n-butylidene chloride. J Pharmacol 3:169–176.
Werner M, Birner G, Dekant W. 1996. Sulfoxidation of mercapturic acids derived from tri-and tetrachloroethene by cytochromes P450 3A: A bioactivation reaction in addition to deacetylation and cysteine conjugate β-lyase mediated cleavage. Chem Res Toxicol 9(1):41–49.8924615
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
White IN, Razvi N, Gibbs AH, . 2001. Neoantigen formation and clastogenic action of HCFC-123 and perchloroethylene in human MCL-5 cells. Toxicol Lett 124(1–3):129–138.11684365
WHO. 1987. Tetrachloroethylene health and safety guide. World Health Organization, Distribution and Sales 1211 Geneva 27, Switzerland, 32.
WHO. 2003. Tetrachloroethene in drinking-water. Background document for development of WHO guidelines for drinking-water quality. Geneva, Switzerland: World Health Organization.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 24, 2013.
WHO. 2011. Guidelines for drinking-water quality. 4th ed. Geneva, Switzerland: World Health Organization. http://www.who.int/water_sanitation_health/publications/2011/dwq_guidelines/en/index.html. April 24, 2013.
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advance treatise. Volume II: The elements Part A. New York NY: Academic Press, 1–247.
Williams P, Benton L, Warmerdam J, . 2002. Comparative risk analysis of six volatile organic compounds in California drinking water. Environ Sci Technol 36(22):4721–4728.12487291
Wilson JT, Enfield CG, Dunlap WJ, . 1981. Transport and fate of selected organic pollutants in a sandy soil. J Environ Qual 10:501–506.
Wilson JT, McNabb JF, Balkwill DL, . 1983. Enumeration and characterization of bacteria indigenous to a shallow water-table aquifer. Ground Water 21:134–142.
Windham GC, Shusterman D, Swan S, . 1991. Exposure to organic solvents and adverse pregnancy outcome. Am J Ind Med 20:241–259.1951371
Windham GC, Zhang L, Gunier R, . 2006. Autism spectrum disorders in relation to distribution of hazardous air pollutants in the San Francisco Bay area. Environ Health Perspect 114(9):1438–1444.16966102
Won D, Corsi RL, Rynes M. 2000. New indoor carpet as an adsorptive reservoir for volatile organic compounds. Environ Sci Technol 34(19):4193–4198.
Wright WH, Bozicevick J, Gordon LS. 1937. Studies on oxyuriasis. V. Therapy with-single doses of tetrachloroethylene. J Am Med Assoc 109:570–573.
Yllner S. 1961. Urinary metabolites of ^14^C-tetrachloroethylene in mice. Nature 191:820.
Yokley KA, Evans MV. 2008. Physiological changes associated with aging result in lower internal doses of toluene and perchloroethylene in simulations using pharmacokinetic modeling. Toxicol Environ Chem 90(3):475–492.
Zapór L, Skowron J, Golofit-Szymczak M. 2002. The cytotoxicity of some organic solvents on isolated hepatocytes in monolayer culture. Int J Occup Saf Ergon 8(1):121–129.11895588
Zhou YH, Cichocki JA, Soldatow VY, . 2017. Editor’s highlight: Comparative dose-response analysis of liver and kidney transcriptomic effects of trichloroethylene and tetrachloroethylene in B6C3F1 mouse. Toxicol Sci 160(1):95–110. 10.1093/toxsci/kfx165.28973375
Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12(1):29–34.643372
Zielhuis GA, Gijsen R, Van Der Gulden JWJ. 1989. Menstrual disorders among dry cleaning workers. Scand J Work Environ Health 15:238.
Ziener CE, Braunsdorf PP. 2014. Trace analysis in end-exhaled air using direct solvent extraction in gas sampling tubes: Tetrachloroethene in workers as an example. Int J Anal Chem 2014:904512. 10.1155/2014/904512.
Ziglio G, Beltramelli G, Pegliaso F. 1984. A procedure for determining plasmatic trichloroacetic acid in human subjects exposed to chlorinated solvents at environmental levels. Arch Environ Contam Toxicol 13:129–134.6721579
Zoccolillo L, Amendola L, Insogna S. 2009. Comparison of atmosphere/aquatic environment concentration ratio of volatile chlorinated hydrocarbons between temperate regions and Antarctica. Chemosphere 76:1525–1532.19541344
Zytner RG, Biswas N, Bewtra JK. 1989. Volatilization of perchloroethylene from stagnant water and soil. In: Bell JM, ed. Proceedings of the 43rd Industrial Waste Conference, Purdue University, May 10–12, 1988. Chelsea, MI: Lewis Publishers, Inc., 101–108.