# PEER REVIEW

A peer review panel was assembled for tetrachloroethylene. The panel are experts who have knowledge of tetrachloroethylene’s physical and chemical properties, toxicokinetics, key health endpoints, mechanisms of action, human and animal exposure, and quantification of risk to humans. All reviewers were selected in conformity with the conditions for peer review specified in Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended. The panel consisted of the following members:

1. Rodney R. Dietert, Ph.D., Professor of Immunotoxicology, College of Veterinary Medicine, Cornell University, Ithaca, New York;
2. Kelly G. Pennell, Ph.D., Civil and Environmental Engineering Department, University of Massachusetts-Dartmouth, North Dartmouth, Massachusetts; and
3. Jill E. Johnston, Ph.D., Department of Environmental Sciences & Engineering, Gillings School of Global Public Health, University of North Carolina, Chapel Hill, North Carolina.

In addition to the above peer reviewers, the following reviewers provided comments on the carcinogenicity discussions in the profile.

1. Neela Guha, Scientist, Ph.D., M.P.H., IARC Monographs Programme, International Agency for Research on Cancer, World Health Organization, Lyon, France
2. Aaron Blair, Ph.D., National Cancer Institute, Division of Cancer Epidemiology and Genetics, Rockville, Maryland
3. Kate Z. Guyton, Ph.D., D.A.B.T., Scientist, IARC Monographs Programme, International Agency for Research on Cancer, World Health Organization, Lyon, France

Scientists from the Agency for Toxic Substances and Disease Registry (ATSDR) have reviewed the peer reviewers’ comments and determined which comments will be included in the profile. A listing of the peer reviewers’ comments and ATSDR’s responses to the comments, exists as part of the administrative record for this compound. The citation of the peer review panel should not be understood to imply its approval of the profile’s final content. The responsibility for the content of this profile lies with the ATSDR.