# UPDATE STATEMENT

A Toxicological Profile for Tetrachloroethylene, Draft for Public Comment was released in October 2014. This edition supersedes any previously released draft or final profile.

Toxicological profiles are revised and republished as necessary. For information regarding the update status of previously released profiles, contact ATSDR at:

- Agency for Toxic Substances and Disease Registry
  Division of Toxicology and Human Health Sciences
  Environmental Toxicology Branch
  1600 Clifton Road NE
  Mailstop S102-1
  Atlanta, Georgia 30329-4027