# 8 REGULATIONS, ADVISORIES, AND GUIDELINES

MRLs are substance-specific estimates that are intended to serve as screening levels. They are used by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites.

ATSDR has derived a chronic-duration inhalation MRL of 0.006 ppm based on color vision impairment in humans chronically exposed to tetrachloroethylene in the workplace at a LOAEL of 7.3 ppm (Cavalleri et al. 1994). The LOAEL was converted to an equivalent continuous exposure concentration of 1.7 ppm (7.3 ppm × 8/24 hours × 5/7 days) and adjusted using an uncertainty factor of 100 (10 for human variability and 10 for use of a LOAEL) and a modifying factor of 3 for database deficiencies (for inadequate information on potential low-dose immune system effects). The chronic-duration inhalation MRL was adopted as the acute- and intermediate-duration inhalation MRLs. A chronic-duration oral MRL of 0.008 mg/kg/day was derived based on route-to-route extrapolation from the chronic-duration inhalation MRL. The chronic-duration oral MRL was adopted as the acute- and intermediate-duration oral MRLs.

IARC has classified tetrachloroethylene as a Group 2A carcinogen (probably carcinogenic to humans) (IARC 2014). The World Health Organization (WHO) has established an air quality guideline value of 0.25 mg/m^3^ for tetrachloroethylene as an annual average (WHO 2010) and a drinking water quality guideline value of 0.04 mg/L for tetrachloroethylene (WHO 2011).

OSHA established a permissible exposure limit (PEL) of 100 ppm for tetrachloroethylene (OSHA 2013b). OSHA has required employers of workers who are occupationally exposed to tetrachloroethylene to institute engineering controls and work practices to reduce and maintain employee exposure at or below the PEL. NIOSH has classified tetrachloroethylene as a potential occupational carcinogen (NIOSH 2013) and established an immediately dangerous to life or health (IDLH) value of 150 ppm. The American Conference of Governmental Industrial Hygienists (ACGIH) has recommended a threshold limit value (TLV) of 25 ppm for an 8-hour workday and a short-term exposure level (STEL) of 100 ppm (ACGIH 2012).

The American Industrial Hygiene Association (AIHA) and the Department of Energy (DOE) have established values for airborne tetrachloroethylene when responding to potential releases for use in community emergency planning (AIHA 2011; DOE 2012). These values represent increasing severity of effects (mild, irreversible, and life threatening) for a 1-hour exposure. Tetrachloroethylene is also designated as a HAP (EPA 2013b).

EPA has classified tetrachloroethylene as likely to be carcinogenic in humans by all routes of exposure (EPA 2012a). NTP has classified tetrachloroethylene as reasonably anticipated to be a human carcinogen (NTP 2016) and ACGIH (2012) has classified tetrachloroethylene as an A3 carcinogen (confirmed animal carcinogen with unknown relevance to humans).

EPA (IRIS 2012) has derived an oral reference dose for tetrachloroethylene of 0.006 mg/kg/day based on route-to-route extrapolation from the inhalation reference concentration. The EPA (IRIS 2012) inhalation reference concentration of 0.04 mg/m^3^ (0.006 ppm) for tetrachloroethylene was derived based on the midpoint between two LOAELs: 15 mg/m^3^(2 ppm) and 56 mg/m^3^(8 ppm) for two controlled human inhalation exposure studies in which neurotoxicity was observed (Cavalleri et al. 1994; Echeverria et al. 1994); an uncertainty factor of 1,000 was applied in the derivation.

EPA has designated tetrachloroethylene as a HAP under the Clean Air Act (CAA) (EPA 2013b). Tetrachloroethylene is on the list of chemicals appearing in “Toxic Chemicals Subject to Section 313 of the Emergency Planning and Community Right-to-Know Act of 1986” and has been assigned a reportable quantity (RQ) limit of 100 pounds (EPA 2012f). The RQ represents the amount of a designated hazardous substance which, when released to the environment, must be reported to the appropriate authority.

Under the Toxic Substances Control Act (TSCA), tetrachloroethylene is on the list of chemicals that manufacturers and importers must report for each plant site at which they manufactured or imported tetrachloroethylene during the reporting period specified (EPA 2012j).

The international and national regulations, advisories, and guidelines regarding tetrachloroethylene in air, water, and other media are summarized in Table 8-1.

Table 8-1 Regulations, Advisories, and Guidelines Applicable to Tetrachloroethylene

Agency | Description | Information | Reference
INTERNATIONAL
Guidelines:
IARC | Carcinogenicity classification | 2A^a^ | IARC 2014
WHO | Air quality guidelines (annual average) | 0.25 mg/m^3^ | WHO 2010
WHO | Drinking water quality guidelines | 0.04 mg/L | WHO 2011
NATIONAL
Regulations and Guidelines:
a. Air
ACGIH | TLV (8-hour TWA) | 25 ppm | ACGIH 2012
ACGIH | STEL | 100 ppm
AIHA | ERPG-1^b,c^ | 100 ppm | AIHA 2011
AIHA | ERPG-2 | 200 ppm
AIHA | ERPG-3 | 1,000 ppm
DOE | PAC-1^d^ | 35 ppm | DOE 2012
DOE | PAC-2 | 230 ppm
DOE | PAC-3 | 1,200 ppm
EPA | AEGL-1^e^ | | EPA 2013a
EPA | 10-minutes | 35 ppm
EPA | 30-minutes | 35 ppm
EPA | 60-minutes | 35 ppm
EPA | 4-hours | 35 ppm
EPA | 8-hours | 35 ppm
EPA | AEGL-2
EPA | 10-minutes | 230 ppm
EPA | 30-minutes | 230 ppm
EPA | 60-minutes | 230 ppm
EPA | 4-hours | 120 ppm
EPA | 8-hours | 81 ppm
EPA | AEGL-3
EPA | 10-minutes | 1,600 ppm
EPA | 30-minutes | 1,600 ppm
EPA | 60-minutes | 1,200 ppm
EPA | 4-hours | 580 ppm
EPA | 8-hours | 410 ppm
EPA | Hazardous air pollutant | Yes | EPA 2013b; 42 USC 7412
EPA | NAAQS | No data | EPA 2013c
NIOSH | REL (10-hour TWA) | Potential occupational carcinogen | NIOSH 2013
NIOSH | IDLH | 150 ppm
OS HA | PEL (8-hour TWA) for general industry | 100 ppm | OSHA 2013b; 29 CFR 1910.1000, Table Z-2
OS HA | Acceptable ceiling concentration | 200 ppm
OS HA | Acceptable maximum peak above the acceptable ceiling concentration for an 8-hour shift | 300 ppm for 5 minutes in any 3 hours
OS HA | Highly hazardous chemicals | No data | OSHA 2013a; 29 CFR 1910.119, Appendix A
b. Water
EPA | Designated as hazardous substances in accordance with Section 311 (b)(2)(A) of the Clean Water Act | No data | EPA 2012b; 40 CFR 116.4
EPA | Drinking water contaminant candidate list | No data | EPA 2009a; 74 FR 51850
EPA | Drinking water standards and health advisories | | EPA 2012c
EPA | One-day (mg/L) in a 10-kg child | 2 mg/L
EPA | Ten-day (mg/L) in a 10-kg child | 2 mg/L
EPA | DWEL | 0.5 mg/L
EPA | Life-time | 0.01 mg/L
EPA | National primary drinking water standards | | EPA 2009b
EPA | MCL^f^ | 0.005 mg/L
EPA | Public health goal | Zero
EPA | National recommended water quality criteria: human health for the consumption of (at 10^−4^ risk) | | EPA 2009c
EPA | Water + organism | 0.69 μg/L
EPA | Organism only | 3.3 μg/L
EPA | Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act | No data | EPA 2012e; 40 CFR 117.3
c. Food
FDA | EAFUS^g^ | No | FDA 2013
d. Other
ACGIH | Carcinogenicity classification | A3^h^ | ACGIH 2012
EPA | Carcinogenicity classification | Likely to be carcinogenic in humans by all routes of exposure | IRIS 2012
EPA | RfC | 0.04 mg/m^3^
EPA | RfD | 0.006 mg/kg/day
EPA | Oral slope factor | 2.1×10^−3^ per mg/kg/day
EPA | Inhalation unit risk | 1.8×10^−3^ per ppm
EPA | Identification and listing of hazardous waste | U210 | EPA 2012d; 40 CFR 261, Appendix VIII
EPA | Inert pesticide ingredients in pesticide products approved for nonfood use only | No data | EPA 2013d
EPA | Master Testing List | Yes^i^ | EPA 2013e
EPA | RCRA waste minimization PBT priority chemical list | No data | EPA 1998; 63 FR 60332
EPA | Standards for owners and operators of hazardous waste TSD facilities; groundwater monitoring list | Yes | EPA 2012f; 40 CFR 264, Appendix IX
EPA | Superfund, emergency planning, and community right-to-know
EPA | Designated CERCLA hazardous substance and reportable quantity pursuant to Section 307(a) of the Clean Water Act, Section 112 of the Clean Air Act, and Section 3001 of RCRA | 100 pounds | EPA 2012g; 40 CFR 302.4
EPA | Effective date of toxic chemical release reporting | 01/01/1987 | EPA 2012h; 40 CFR 372.65
EPA | Extremely hazardous substances and its threshold planning quantity | No data | EPA 2012i; 40 CFR 355, Appendix A
EPA | TSCA chemical lists and reporting periods | No data | EPA 2012j; 40 CFR 712.30
EPA | TSCA health and safety data reporting | | EPA 2012k; 40 CFR 716.120
EPA | Effective date | 06/01/1987
EPA | Reporting date | 06/01/1997
NTP | Carcinogenicity classification | Reasonably anticipated to be a human carcinogen | NTP 2016

a Group 2A: probably carcinogenic to humans.

b ERPG-1: maximum airborne concentration below which it is believed that nearly all individuals could be exposed for up to 1 hour without experiencing other than mild transient adverse health effects or perceiving a clearly defined, objectionable odor; ERPG-2: maximum airborne concentration below which it is believed that nearly all individuals could be exposed for up to 1 hour without experiencing or developing irreversible or other serious health effects or symptoms that could impair an individual’s ability to take protective action; ERPG-3: is the maximum airborne concentration below which it is believed that nearly all individuals could be exposed for up to 1 hour without experiencing or developing life-threatening health effects (AIHA 2011).

c Odor should be detectable near ERPG-1.

d PAC-1: mild, transient health effects; PAC-2: irreversible or other serious health effects that could impair the ability to take protective action; PAC-3: life-threatening health effects (DOE 2012).

e AEGL-1: the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience notable discomfort, irritation, or certain asymptomatic, nonsensory effects; however, these effects are not disabling and are transient and reversible upon cessation of exposure; AEGL-2: the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience irreversible or other serious, long-lasting, adverse health effects or an impaired ability to escape; AEGL-3: the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience life-threatening adverse health effects or death (EPA 2013a).

f Potential health effects from long-term exposure above the MCL could cause liver problems and increased risk of cancer; common sources of contaminant in drinking water include discharges from factories and dry cleaners (EPA 2009b).

g The EAFUS list of substances contains ingredients added directly to food that FDA has either approved as food additives or listed or affirmed as GRAS.

h A3: confirmed animal carcinogen with unknown relevance to humans.

i Testing action development underway for acute development and immunological health effects.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; AIHA = American Industrial Hygiene Association; CERCLA = Comprehensive Environmental Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; ERPG = emergency response planning guidelines; FDA = Food and Drug Administration; FR = Federal Register; GRAS = generally recognized as safe; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; MCL = maximum contaminant level; NAAQS = National Ambient Air Quality Standards; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PBT = persistent, bioaccumulative, and toxic; PEL = permissible exposure limit; RCRA = Resource Conservation and Recovery Act; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; STEL = short-term exposure level; TLV = threshold limit values; TSCA = Toxic Substances Control Act; TSD = treatment, storage, and disposal; TWA = time-weiahted averaae: USC = United States Code: WHO = World Health Oraanization