# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

The chemical identity of tetrachloroethylene is shown in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

The physical and chemical properties of tetrachloroethylene are shown in Table 4-2.

Table 4-1 Chemical Identity of Tetrachloroethylene

Characteristic | Information | Reference
Chemical name | Tetrachloroethylene | HSDB 2013
Synonym(s) | Ethylene tetrachloride; per; PERC; perchlor; perchloroethylene; perk; 1,1,2,2-tetrachloroethylene; tetrachloroethene; tetrachloroethylene; PCE | HSDB 2013;; NIOSH 2013
Registered trade name(s) | Ankilostin; Antisal 1; Dee-Solve; Didakene; Dow-per; ENT 1860; Fedal-Un; Nema; Perclene; Percosolv; Perklone; PerSec; Tetlen; Tetracap; Tetraleno; Tetravec; Tetroguer; Tetropil; Perawin; Tetralex; Dowclene EC | OHM/TADS 1990
Chemical formula | C_2_Cl_4_ | HSDB 2013
Chemical structure | Figure description | HSDB 2013
Identification numbers:
CAS registry | 127-18-4 | HSDB 2013
NIOSH RTECS | kx3850000 | HSDB 2013
EPA hazardous waste | U210 | HSDB 2013
OHM/TADS | 7216847 | OHM/TADS 1990
DOT/UN/NA/IMDG shipping | UN1897; IMO 6.1 | HSDB 2013
HSDB | 49 403 55 | HSDB 2013
NCI | NCI-C04580 | HSDB 2013

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Tetrachloroethylene

Property | Information | Reference
Molecular weight | 165.83 | Lide 2008
Color | Colorless | HSDB 2013
Physical state | Liquid (at room temperature) | HSDB 2013
Melting point | -22.3°C | Lide 2008
Boiling point | 121.3°C | Lide 2008
Density at 20 °C | 1.6230 g/mL | Lide 2008
Odor | Ethereal | HSDB 2013
Odor threshold:
Water | 0.3 ppm | EPA 1987
Air | 1.0 ppm | EPA 1987
Solubility:
Water at 25 °C | 206 mg/L | HSDB 2013
Organic solvents | Miscible with alcohol, ether, chloroform, benzene, solvent hexane, and most of the fixed and volatile oils | HSDB 2013
Partition coefficients:
Log K_ow_ | 3.40 | HSDB 2013
Log K_oc_ | 2.2–2.54 | Friesel et al. 1984; Seip et al. 1986;
Vapor pressure at 20 °C | 18.5 mmHg | HSDB 2013
Henry’s law constant at 25 °C | 1.8×10^−2^ atm-m^3^/mol | Gossett 1987
Autoignition temperature | No data
Flashpoint | None | HSDB 2013
Flammability limits | Nonflammable | HSDB 2013
Conversion factors | 1 mg/L = 147.4 ppm; 1 ppm = 6.78 mg/m3 | HSDB 2013
Explosive limits | No data