# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

## Tetrachloroethylene Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Tetrachloroethylene
CAS Numbers: | 127-18-4
Date: | June 2019
Profile Status: | Final
Route: | [x] Inhalation [ ] Oral
Duration: | [x] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 128
Species: | Human

[underlined: Minimal Risk Level]: 0.006 [ ] mg/kg/day [x] ppm

[underlined: Reference]: Cavalleri A; Gobba F; Paltrinieri M; . 1994. Perchloroethylene exposure can induce colour vision loss. Neurosci Lett 179:162–166.7845613

[underlined: Experimental design]: See worksheet for chronic inhalation MRL.

[underlined: Effects noted in study and corresponding doses]: See worksheet for chronic inhalation MRL.

[underlined: Dose and end point used for MRL derivation]: See worksheet for chronic inhalation MRL.

[ ] NOAEL [ x ] LOAEL

1.7 ppm

[underlined: Uncertainty Factors used in MRL derivation]:

- [x] 10 for use of a LOAEL
- [ ] 10 for extrapolation from animals to humans
- [x] 10 for human variability

[underlined: Modifying Factors used in MRL derivation]:

- [x] 3 for database deficiencies (inadequate information on low-dose immune system effects)

[underlined: Was a conversion used from ppm in food or water to a mg/body weight dose?] Not applicable.

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose:] Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? See worksheet for chronic inhalation MRL.

[underlined: Other additional studies or pertinent information which lend support to this MRL]: Data available for acute-duration inhalation MRL derivation include three controlled human exposure studies and several animal studies. The lowest effect levels were identified in the human exposure studies by Altmann et al. (1990, 1992). In the study by Altmann et al. (1992), male volunteers were exposed to tetrachloroethylene at 10 or 50 ppm, 4 hours/day for 4 days. Corresponding equivalent continuous exposure concentrations are 2 and 10 ppm. At 50 ppm, pattern reversal visual-evoked potential latencies increased (p<0.05) and significant performance deficits for vigilance (p=0.04) and eye-hand coordination (p=0.05) were observed. No effects on brainstem auditory-evoked potential were noted at either concentration. Because a faint odor was reported by 33% of the subjects at 10 ppm and 29% of the subjects at 50 ppm on the first day of testing, and by 15% of the subjects at 10 ppm and 36% of the subjects at 50 ppm on the last day of testing, the investigators concluded that only a few subjects could identify their exposure condition. In a similar study by Altmann et al. (1990), significant (p<0.05) increased latencies for pattern reversal visual-evoked potentials were observed in 10 male volunteers exposed to tetrachloroethylene at 50 ppm, compared to 12 men exposed at 10 ppm. Exposures in this study were also 4 hours/day for 4 days, resulting in equivalent continuous exposure concentrations of 2 and 10 ppm. Effects on brainstem auditory-evoked potentials were not observed in the Altmann et al. (1990) study. Tetrachloroethylene in the blood increased with exposure duration, and linear regression to associate blood tetrachloroethylene with pattern reversal visual-evoked potential latencies was significant (r=-0.45, p<0.03). Additional tests of neurological function were not conducted in this study. These two studies identified a NOAEL of 10 ppm (2 ppm equivalent continuous exposure concentration).

Hake and Stewart (1977) did not find any changes in flash-evoked potentials or equilibrium tests in four male subjects exposed to increasing concentrations of tetrachloroethylene 7.5 hours/day for 5 days. The subjects were sequentially exposed to 0, 20, 100, and 150 ppm (each concentration 1 week). Corresponding equivalent continuous exposure concentrations are 6.25, 31, and 47 ppm. Subjective evaluation of EEG scores suggested cortical depression in subjects exposed at 100 ppm. Decreases in the Flanagan coordination test were observed at ≥100 ppm.

Animal studies of acute-duration exposure to tetrachloroethylene have demonstrated neurological effects, but at higher concentrations than the human study by Altmann et al. (1990) (>16 ppm continuous equivalent concentration; Boyes et al. 2009; De Ceurriz et al. 1983; Mattsson et al. 1998; NTP 1986; Oshiro et al. 2008; Savolainen et al. 1977). PBPK modeling simulations suggest equivalent tetrachloroethylene blood AUCs for rats and humans exposed to the same inhaled concentrations (Chiu and Ginsberg 2011), indicating that the human-equivalent concentrations for these studies are also ≥16 ppm and higher than the human effect levels identified by Altmann et al. (1990, 1992). Thus, animal studies were not considered to be suitable options for acute-duration MRL derivation.

An acute-duration inhalation MRL could be obtained using the controlled human exposure study by Altmann et al. (1990, 1992). This study identified a NOAEL of 2 ppm (equivalent continuous exposure concentration) for neurobehavioral changes. This value is equal to the LOAEL of 1.7 ppm for color vision decrements in the chronic-duration epidemiological study by Cavalleri et al. (1994). Given that the NOAEL was from a study in which exposures were for only 4 hours/day for 4 days, it is uncertain whether this value would be adequately protective for longer exposures (up to 2 weeks). In male volunteers exposed to 1 ppm tetrachloroethylene for 6 hours, venous blood concentrations continued to increase between 4 and 6 hours (Chiu et al. 2007); likewise, when venous blood was sampled before each of four daily 4-hour exposures to tetrachloroethylene at 10 or 50 ppm, concentrations continued to increase each day from 36 μg/L before the second exposure to 10 ppm up to 56 μg/L 1 day after the fourth daily exposure (Altmann et al. 1990). These data suggest that continuous or repeated exposures over durations longer than 4 days may yield higher blood levels than seen after four daily 4-hour exposures, and that the NOAEL of 2 ppm observed in the study by Altmann et al. (1990) may not be adequately protective for exposures up to 2 weeks. Because it is very close to the NOAEL from acute-duration exposure, the chronic-duration LOAEL of 1.7 ppm (continuous equivalent exposure concentration) from Cavalleri et al. (1994) may represent a better basis for acute- and intermediate-duration MRLs. A PBPK model (Chiu and Ginsberg 2011) was used to evaluate the effect of exposure duration on the AUC of the blood concentration-time curve at a continuous exposure of 1.7 ppm. While it is not certain whether the neurological effects of tetrachloroethylene result from the parent compound or one or more of its metabolites, the AUC of the tetrachloroethylene blood concentration-time curve is assumed to represent a reasonable surrogate for the internal dose of the ultimate toxicant(s). This simulation showed that the 24-hour AUC blood concentration-time values are very similar after 14 days, 90 days, 365 days, and 2 years of exposure (see Table A-1 below). These simulations predict that the blood AUC of tetrachloroethylene is nearly constant after 2 weeks of continuous exposure. The blood concentration reaches approximately 90% of steady state at about 2 weeks of continuous exposure and 99% of steady state at 90 days. Given that the tetrachloroethylene AUC after acute-duration exposure is very similar to that after chronic exposure to the same concentration, the chronic MRL was adopted as the acute-duration MRL.

Table A-1 Predicted Effect of Exposure Duration on Human Blood Levels of Tetrachloroethylene During Continuous (24 Hours/day, 7 Days/week) Inhalation Exposure to 1.7 ppm

PBPK dose metric | Exposure duration (days)
PBPK dose metric | 14 | 90 | 365 | 728
Area under the blood concentration-time curve (mg-24 hour/L per ppm) | 1.799 | 1.999 | 2.029 | 2.033

[underlined: Agency Contact (Chemical Manager)]: Rae Benedict

## Tetrachloroethylene Intermediate Inhalation Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Tetrachloroethylene
CAS Numbers: | 127-18-4
Date: | June 2019
Profile Status: | Final
Route: | [x] Inhalation [ ] Oral
Duration: | [ ] Acute [x] Intermediate [ ] Chronic
Graph Key: | 128
Species: | Human

[underlined: Minimal Risk Level]: 0.006 [ ] mg/kg/day [x] ppm

[underlined: Reference]: Cavalleri A; Gobba F; Paltrinieri M; . 1994. Perchloroethylene exposure can induce colour vision loss. Neurosci Lett 179:162–166.7845613

[underlined: Experimental design]: See worksheet for chronic inhalation MRL.

[underlined: Effects noted in study and corresponding doses]: See worksheet for chronic inhalation MRL.

[underlined: Dose and end point used for MRL derivation]:

[ ] NOAEL [ x ] LOAEL

1.7 ppm

[underlined: Uncertainty Factors used in MRL derivation]:

- [x] 10 for use of a LOAEL
- [ ] 10 for extrapolation from animals to humans
- [x] 10 for human variability

[underlined: Modifying Factors used in MRL derivation]:

- [x] 3 for database deficiencies (inadequate information on low-dose immune system effects)

[underlined: Was a conversion used from ppm in food or water to a mg/body weight dose?] Not applicable.

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose:] Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? See worksheet for chronic inhalation MRL.

[underlined: Other additional studies or pertinent information which lend support to this MRL]: Available intermediate-duration studies that examined or observed neurological or neurobehavioral effects in animals (e.g., Karlsson et al. 1987; Kyrklund et al. 1988, 1990; Mattsson et al. 1992, 1998; Rosengren et al. 1986; Tinston 1995; Wang et al. 1993) identified effect levels much higher than the acute-duration human studies (Altmann et al. 1990, 1992; Hake and Stewart 1977). In addition, the available data suggest that low effect levels in humans from acute-duration exposure are similar to those for the chronic-duration LOAEL of 1.7 ppm (continuous equivalent exposure concentration) from Cavalleri et al. (1994), suggesting that the same MRL may be applicable to all exposure durations. A PBPK model (Chiu and Ginsberg 2011) was used to evaluate the effect of exposure duration on the AUC of the blood concentration-time curve at a continuous exposure of 1.7 ppm. While it is not certain whether the neurological effects of tetrachloroethylene result from the parent compound or one or more of its metabolites, the AUC of the tetrachloroethylene blood concentration-time curve is assumed to represent a reasonable surrogate for the internal dose of the ultimate toxicant(s). This simulation showed that and 24-hour AUC values are very similar after 14 days, 90 days, 365 days, and 2 years of exposure (see Table A-2). These simulations predict that the blood AUC of tetrachloroethylene is nearly constant after 2 weeks of continuous exposure. The blood concentration reaches approximately 90% of steady state at about 2 weeks of continuous exposure and 99% of steady state at 90 days. Given that the tetrachloroethylene AUC after intermediate-duration exposure is the same as that after chronic exposure to the same concentration, the chronic MRL was adopted as the intermediate-duration MRLs.

Table A-2 Predicted Effect of Exposure Duration on Human Blood Levels of Tetrachloroethylene During Continuous (24 Hours/day, 7 Days/week) Inhalation Exposure to 1.7 ppm

PBPK dose metric | Exposure duration (days)
PBPK dose metric | 14 | 90 | 365 | 728
AUC (mg-24 hour/L per ppm) | 1.799 | 1.999 | 2.029 | 2.033

[underlined: Agency Contact (Chemical Manager)]: Rae Benedict

## Tetrachloroethylene Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Tetrachloroethylene
CAS Numbers: | 127-18-4
Date: | June 2019
Profile Status: | Final
Route: | [x] Inhalation [ ] Oral
Duration: | [ ] Acute [ ] Intermediate [x] Chronic
Graph Key: | 128
Species: | Human

[underlined: Minimal Risk Level]: 0.006 [ ] mg/kg/day [x] ppm

[underlined: Reference]: Cavalleri A; Gobba F; Paltrinieri M; . 1994. Perchloroethylene exposure can induce colour vision loss. Neurosci Lett 179:162–166.7845613

Gobba F; Righi E; Fantuzzi G; . 1998. Two-year evolution of perchloroethylene-induced color-vision loss. Arch Environ Health 53:196–198.9814715

[underlined: Experimental design]: Color vision was evaluated in 35 tetrachloroethylene-exposed workers (22 dry cleaners and 13 ironers) with an average of 106 months of exposure. Concentrations were measured in the breathing zone by personal passive samplers. The TWA concentrations for all workers ranged from 0.38 to 31.19 ppm, with mean exposures of 6.23, 7.27, and 4.80 ppm for all workers, dry cleaners, and ironers, respectively. Controls included an equal number (35) of workers without occupational exposure to solvents, and were matched for sex, age, alcohol consumption, and cigarette smoking. Color vision was evaluated by the Lanthany 15 Hue desaturated panel (D-15d) test, which is designed for early detection of acquired dyschromatopsia. The results of the test were expressed as Color Confusion Index (CCI). The subjects were reexamined 2 years later using the same test; results were reported by Gobba et al. (1998).

[underlined: Effects noted in study and corresponding doses]: The results of the color vision test showed a significant decrease in color vision (mainly blue-yellow range) in the dry cleaners exposed to a mean concentration of 7.3 ppm. No significant difference in color vision was found for a group of 13 ironers who experienced exposures to a lower average concentration (4.8 ppm). For the entire group of 35 workers (dry cleaners plus ironers), a multivariate analysis showed a significant association between increasing tetrachloroethylene concentration and decreased color vision (p<0.01). This association was highly influenced by outcomes for three subjects whose exposures exceeded 12.5 ppm. Mean (±standard deviation) CCI scores were 1.192±0.133 in dry cleaners compared with 1.089±0.117 in controls (p=0.007). Reexamination of the workers 2 years later showed that those workers whose exposure to tetrachloroethylene had increased (from a geometric mean concentration of 1.67–4.35 ppm, p<0.01) experienced further decrements in color vision (from a mean CCI of 1.16–1.26, p<0.01), after controlling for age (which showed a significant association with increasing CCI), while those whose exposure had decreased (from a geometric mean concentration of 2.95–0.66 ppm) experienced no change in CCI (Gobba et al. 1998). Exposures to tetrachloroethylene were highly variable in the Cavalleri et al. (1994) study, varying by as much as 10-fold for certain job activities, and it is possible that the disturbances to color vison were more strongly related to the highest concentrations of tetrachloroethylene observed. The TWA exposure level (7.3 ppm), reported in Cavalleri et al. (1994) was selected as the exposure metric for deriving the MRL because it was the metric used in the statistical analyses that formed the basis for the association between exposure and effects on color vision. The 7.3 ppm concentration was multiplied by 8/24 hours and 5/7 days to yield an equivalent continuous exposure concentration of 1.7 ppm. This conversion assumes linear pharmacokinetics at exposures ≤7.3 ppm (Chiu and Ginsberg 2011). The 1.7 ppm concentration was considered a LOAEL for decreased color vision and was used to derive the chronic MRL.

The Cavalleri et al. (1994) and Gobba et al. (1998) studies have some important limitations for deriving exposure-response relationship for effects of tetrachloroethylene on the visual system. The study included a relatively small number of subjects (n=35) who may have experienced exposures to other solvents. Exposure estimates were based on personal air monitoring conducted on a single day, which may be an uncertain metric for long-term exposure of individuals. However, it is not certain whether long-term cumulative exposure is an important determinant of central nervous system and/or visual impairment induced by tetrachloroethylene. Studies conducted in rodents suggest that acute (<15 days) of exposure to tetrachloroethylene can result in changes to visual-evoked potentials (Albee et al. 1991; Boyes et al. 2009; Mattsson et al. 1998), EEG patterns (Albee et al. 1991), and performance neurobehavioral tests (Oshiro et al. 2008; Savolainen et al. 1977). Therefore, it is possible that the concurrent measurements of exposure, such as those reported in the Cavalleri et al. (1994) and Gobba et al. (1998) studies, are relevant dose-metrics for visual disturbances.

[underlined: Dose and end point used for MRL derivation]:

[ ] NOAEL [ x ] LOAEL

1.7 ppm, increased CCI

[underlined: Uncertainty Factors used in MRL derivation]:

- [x] 10 for use of a LOAEL
- [ ] 10 for extrapolation from animals to humans
- [x] 10 for human variability

Several genetic polymorphisms in enzymes that are involved in tetrachloroethylene metabolism (e.g., GST, NAT) may contribute to variability in tetrachloroethylene toxicokinetics (Chiu and Ginsberg 2011; Spearow et al. 2017). Together with toxicodynamic uncertainty, these support a total uncertainty factor of 10 for human variability.

[underlined: Modifying Factors used in MRL derivation]:

- [x] 3 for database deficiencies (inadequate information on low-dose immune system effects)

[underlined: Was a conversion used from ppm in food or water to a mg/body weight dose?] No.

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose;][underlined: was a conversion used from intermittent to continuous exposure]? To convert from occupational exposure to continuous exposure, the 7.3 ppm concentration was multiplied by 8/24 hours and 5/7 days to yield an equivalent continuous exposure concentration of 1.7 ppm. This conversion assumes linear pharmacokinetics at exposures ≤7.3 ppm (Chiu and Ginsberg 2011).

[underlined: Other additional studies or pertinent information which lend support to this MRL]: The nervous system is a well-established target of tetrachloroethylene exposure in humans and animals, and effects on this system occur at lower concentrations than effects in other target organs such as the liver or kidney. There is a substantial number of studies evaluating the effects of inhaled tetrachloroethylene in occupationally exposed individuals, particularly those engaged in dry cleaning activities. More recent studies have also examined residential populations living in buildings that also housed dry cleaning facilities or in buildings in close proximity to such facilities. The human epidemiological studies (especially Cavalleri et al. 1994; Echeverria et al. 1995; Gobba et al. 1998; Schneiber et al. 2002; Seeber 1989; Storm et al. 2011), combined with a small number of human controlled exposure experiments (Altmann et al. 1990; Hake and Stewart 1977), have identified central nervous system effects after acute-, intermediate-, and chronic-duration exposures to tetrachloroethylene.

Storm et al. (2011) recruited adults and children living in New York City buildings with or without colocated dry cleaners for a larger study of visual acuity and contrast sensitivity. There were a number of differences between the exposed and referent groups with respect to education, race/ethnicity, and income. The exposed subjects were stratified into low and high exposure (<100 or >100 μg/m^3^ tetrachloroethylene) groups based on 24-hour air samples; exhaled air and blood were also analyzed for tetrachloroethylene. Geometric mean indoor air concentrations of 0.00046, 0.0018, or 0.050 ppm tetrachloroethylene were reported for the referent, low, and high exposure groups of children (n=56, 39, and 11, respectively); for adult participants, the respective concentrations were 0.00043, 0.0017, or 0.070 ppm (n=49, 43, and 12, respectively). Visual acuity testing was limited to far distance visual contrast only, and the response was scored as either perfect or less than perfect. In children, a higher concentration of tetrachloroethylene in indoor air was associated with a higher odds of achieving less than the maximum score (in the poorer performing eye) at a spatial frequency of 12 cycles per degree of visual arc; the effect remained after adjustment for race, ethnicity, and age (adjusted OR of 2.64; 95% CI 1.41–5.52). Visual contrast sensitivity of adults was not associated with measures of tetrachloroethylene exposure. Due to the limitations of this study, including the use of an insensitive vision test and differences between exposed and referent populations that were not accounted for, this study is not considered to be a candidate for MRL derivation.

Schreiber et al. (2002) evaluated a group of residents (n=17) and a group of daycare workers (n=9), each of whom was exposed to tetrachloroethylene for an average of 4 or 5.8 years, respectively, originating from a dry cleaner that was co-located with the residence or daycare. Age- and sex-matched controls without exposure consisted of New York State Department of Health (NYSDOH) employees. Visual acuity, color discrimination, and contrast sensitivity were assessed in these groups; investigators involved in vision testing were not blinded to the exposure status. Ambient and personal air monitoring results suggested mean concentrations of about 0.11 ppm among the residents and about 0.3 ppm among the daycare workers. In both groups, significant (p<0.001) decreases in visual contrast sensitivity were observed when compared with the unexposed referent groups. Due to limitations of this study, including small sample size (17 exposed and 17 controls), selection bias in choice of referent population (NYSDOH employees), and vision testing by investigators not blinded to exposure status, it was not selected for use in MRL derivation.

Altmann et al. (1995) evaluated neurobehavioral effects of tetrachloroethylene in 14 persons living above or next to dry cleaning facilities for 1–30 years compared with 23 unexposed controls. The median concentrations of tetrachloroethylene were 0.2 and 0.003 ppm in the apartments of exposed and control subjects, respectively; blood concentrations measured in the examination room (not in the apartments) were 17.8±46.9 μg/L (mean±standard deviation) in exposed subjects and below the 0.5 μg/L detection limit in controls. A neurological test battery, including pattern reversal visual-evoked potentials, continuous performance test, hand-eye coordination, finger tapping, simple reaction time, and visual memory, was administered to both groups. No significant differences between the groups were observed when the unadjusted test results were compared (Altmann et al. 1995). However, when results were analyzed using multivariate analysis to adjust for age, gender, and education, response times in the continuous performance test and simple reaction time were increased (p<0.05), and a smaller number of stimuli were identified correctly by the exposed subjects (p<0.05) relative to 23 controls. Limitations of this study include its small sample size and differences in educational level between the exposed and referent groups.

Performance on neurobehavioral tests was also assessed in a study of 65 dry cleaning workers exposed to tetrachloroethylene for at least 1 year (Echeverria et al. 1995). The workers were grouped into low, medium, or high exposure categories based on job title and years of employment. Exposure estimates for the three categories were based on air concentrations measured in the breathing zone of clerks, pressers, and operators (8-hour TWA concentrations were 11.2, 23.2, and 40.8 ppm, respectively).

Neurobehavioral tests that measured short-term memory for visual designs showed deficits in the high-exposure group (40.8 ppm) relative to the low-exposure group (11.2 ppm). After adjustment for potential confounding, scores for pattern recognition, pattern memory, and visual reproduction were significantly reduced (4, 7, and 14%, respectively; p<0.01) in the high-exposure group compared with the low-exposure group. Echeverria et al. (1995) also described four cases referred for neuropsychologic assessment of possible tetrachloroethylene encephalopathy. The subjects performed below expectation on tasks assessing memory, motor, visuospatial, and executive functions, with milder attentional deficits.

Performance on neurobehavioral tests was assessed in 101 dry cleaning workers exposed to tetrachloroethylene for 11–12 years (Seeber 1989). The workers were grouped into low or high exposure categories based on job title and room air measurements at each work location (TWA concentration of 12 or 54 ppm). Low- and high-exposure groups had significantly impaired perceptual function, attention, and intellectual function compared to a population of 84 controls, when evaluated by a battery of psychological tests and questionnaires. The workers were exposed on average 12 and 11 years in the low- and high-exposure groups, respectively (as reported by EPA 2012a). The study showed statistically significant differences, indicative of impairment, between exposed and control groups in test scores for neurological signs, emotional lability, perceptual speed, delayed reactions, digit reproduction, cancellation d2 (fault corrected performance), and digit symbol, after controlling for gender, age, and intelligence. Among these tests, only scores for perceptual speed, delayed reactions, and digit reproduction exhibited monotonic dose-response relationships; for the other tests, the scores were worse in the low-exposure group than in the high-exposure group.

Neurological effects of tetrachloroethylene exposure in laboratory rodents are qualitatively similar to those seen in human studies. Mice and rats have exhibited anesthetic effects after acute exposure to high concentrations of tetrachloroethylene (Friberg et al. 1953; Goldberg et al. 1964; NTP 1986; Rowe et al. 1952). Rats exposed to 3,000 ppm tetrachloroethylene became anesthetized in several hours, while those exposed to 6,000 ppm were anesthetized in minutes (Rowe et al. 1952). Anesthesia was observed in mice within 2.5 minutes of breathing air containing 6,800 ppm tetrachloroethylene (Friberg et al. 1953). Mice inhaling tetrachloroethylene for 4 hours showed signs of anesthesia at a concentration of 2,328 ppm (NTP 1986). Rats became ataxic following exposure to 2,300 ppm for 4 hours (Goldberg et al. 1964).

Dyspnea, hypoactivity, hyperactivity, anesthesia, and ataxia were noted in mice and rats exposed to 1,750 ppm for 6 hours/day, 5 days/week for 2 weeks; these effects were not seen at lower concentrations (up to 875 ppm) (NTP 1986). Lower concentrations have resulted in effects on visual-evoked potentials (Albee et al. 1991; Boyes et al. 2009; Mattsson et al. 1998), EEG patterns (Albee et al. 1991), and neurobehavioral tests (Oshiro et al. 2008; Savolainen et al. 1977), as well as brain chemistry (Karlsson et al. 1987; Kyrklund et al. 1988; Rosengren et al. 1986; Wang et al. 1993) in laboratory rodents or gerbils. Male Long-Evans rats exposed for 1.5 hours to concentrations of 250, 500, or 1,000 ppm exhibited reduced amplitude of visual evoked potentials at all exposure concentrations (Boyes et al. 2009). Albee et al. (1991) reported electrophysiological changes including altered shape, reduced amplitude, and decreased latency of flash-evoked potentials; decreased latency of somatosensory evoked potentials; and EEG changes in male rats exposed to tetrachloroethylene at 800 ppm 4 hours/day for 4 days. Similar findings were observed when male F344 rats were exposed 6 hours/day for 4 days to 800 ppm tetrachloroethylene as a pilot study in preparation for a subchronic study (Mattsson et al. 1998). Impairment of sustained attention was observed in male Long-Evans rats exposed for 1 hour to concentrations ≥500 ppm tetrachloroethylene (Oshiro et al. 2008). Open-field behavior (ambulation) was elevated in groups of 10 male rats exposed to 200 ppm tetrachloroethylene of unspecified purity for 6 hours/day for 4 days (Savolainen et al. 1977). Ambulation was significantly increased 1 hour, but not 17 hours, after the last exposure (Savolainen et al. 1977).

In addition, brain chemistry has been altered in laboratory rodents or gerbils exposed to tetrachloroethylene (Karlsson et al. 1987; Kyrklund et al. 1984, 1988; Rosengren et al. 1986; Wang et al. 1993). Gerbils exposed to 320 ppm continuously for 3 months followed by a 4-month exposure-free period had changes in levels of S-100 protein, a marker for astrocytes as well as other cells in the peripheral nervous system and skin (Rosengren et al. 1986). Rats exposed to 320 ppm continuously for 30 days had changes in brain cholesterol, lipids, and polyunsaturated fatty acids (Kyrklund et al. 1988). Changes in the fatty acid composition of the brain were also observed in rats continuously exposed to tetrachloroethylene at 320 ppm for 90 days (Kyrklund et al. 1990). Gerbils exposed to 60 or 320 ppm had decreased DNA content in portions of the cerebrum (Karlsson et al. 1987; Rosengren et al. 1986). Gerbils exposed to 120 ppm continuously for 12 months had altered phospholipid content (phosphatidylethanolamine) in the cerebral cortex and hippocampus (Kyrklund et al. 1984). In rats exposed to 600 ppm tetrachloroethylene continuously for 4 weeks, cytoskeletal elements of neuronal cells (neurofilament 68 kD polypeptide) were significantly reduced in the frontal cerebral cortex, hippocampus, and brainstem; after 12 weeks at this concentration, a cytosolic marker (glial S-100) and cytoskeletal elements of glial cells (glial fibrillary acid protein) were also significantly reduced in all three brain regions (Wang et al. 1993).

[underlined: Agency Contact (Chemical Manager)]: Rae Benedict

## Tetrachloroethylene Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Tetrachloroethylene
CAS Numbers: | 127-18-4
Date: | June 2019
Profile Status: | Final
Route: | [ ] Inhalation [x] Oral
Duration: | [x] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 128 (see Figure 3-1)
Species: | Human

[underlined: Minimal Risk Level]: 0.008 [x] mg/kg/day [ ] ppm

[underlined: Reference]: Cavalleri A; Gobba F; Paltrinieri M; . 1994. Perchloroethylene exposure can induce colour vision loss. Neurosci Lett 179:162–166.7845613

Gobba F; Righi E; Fantuzzi G; . 1998. Two-year evolution of perchloroethylene-induced color-vision loss. Arch Environ Health 53:196–198.9814715

[underlined: Experimental design]: See worksheet for chronic-duration inhalation MRL.

[underlined: Effects noted in study and corresponding doses]: See worksheet for chronic-duration inhalation MRL.

[underlined: Dose and end point used for MRL derivation]:

[ ] NOAEL [ x ] LOAEL

2.3 mg/kg/day, increased Color Confusion Index (CCI), estimated by route-to-route extrapolation from continuous-equivalent inhalation exposure concentration of 1.7 ppm.

[underlined: Uncertainty Factors used in MRL derivation]:

- [x] 10 for use of a LOAEL
- [ ] 10 for extrapolation from animals to humans
- [x] 10 for human variability

[underlined: Modifying Factors used in MRL derivation]:

- [x] 3 for database deficiencies (inadequate information on low-dose immune system effects) [underlined: Was a conversion used from ppm in food or water to a mg/body weight dose?] Not applicable.

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose:] Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? See worksheet for chronic-duration inhalation MRL.

[underlined: Other additional studies or pertinent information which lend support to this MRL]: There is abundant evidence for neurological and neurobehavioral effects after chronic, low exposures to tetrachloroethylene. While this evidence is primarily available from studies of inhalation exposure, effects after oral exposure are expected to be similar based on the available oral data and pharmacokinetic studies suggesting similar blood levels of parent compound after inhalation and oral exposure of humans to tetrachloroethylene (see for example, the PBPK model by Chiu and Ginsberg [2011]). Among human and animal studies identifying neurological or neurobehavioral effects after acute-duration oral exposure, the lowest effect level was identified by Fredrikkson et al. (1993). Fredriksson et al. (1993) identified a LOAEL of 5 mg/kg/day for hyperactivity in male NMRI mice exposed via gavage for 7 days beginning on postnatal day 10 (Fredriksson et al. 1993). Significant pharmacokinetic differences between mice and humans lead to markedly different blood levels of parent compound after oral exposure to tetrachloroethylene; thus, mice are not a good model for neurological effects of tetrachloroethylene exposure in humans. Other acute-duration studies evaluating neurological responses used doses at least 10-fold higher. In addition, the LOAEL of 5 mg/kg/day identified in mice is similar to the POD of 2.3 mg/kg/day for the chronic oral MRL. Given the lack of suitable acute-duration oral data, and the observation that neurobehavioral effect levels for acute-duration exposure in humans are similar to those for chronic-duration exposure, the acute oral MRL was set equal to the chronic oral MRL.

[underlined: Agency Contact (Chemical Manager)]: Rae Benedict

## Tetrachloroethylene Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Tetrachloroethylene
CAS Numbers: | 127-18-4
Date: | June 2019
Profile Status: | Final
Route: | [ ] Inhalation [x] Oral
Duration: | [ ] Acute [x] Intermediate [ ] Chronic
Graph Key: | 128 (see Figure 3-1)
Species: | Human

[underlined: Minimal Risk Level]: 0.008 [x] mg/kg/day [ ] ppm

[underlined: Reference]: Cavalleri A; Gobba F; Paltrinieri M; . 1994. Perchloroethylene exposure can induce colour vision loss. Neurosci Lett 179:162–166.7845613

Gobba F; Righi E; Fantuzzi G; . 1998. Two-year evolution of perchloroethylene-induced color-vision loss. Arch Environ Health 53:196–198.9814715

[underlined: Experimental design]: See worksheet for chronic-duration inhalation MRL.

[underlined: Effects noted in study and corresponding doses]: See worksheet for chronic-duration inhalation MRL.

[underlined: Dose and end point used for MRL derivation]:

[ ] NOAEL [ x ] LOAEL

2.3 mg/kg/day, increased Color Confusion Index (CCI), estimated by route-to-route extrapolation from continuous- equivalent inhalation exposure concentration of 1.7 ppm.

[underlined: Uncertainty Factors used in MRL derivation]:

- [x] 10 for use of a LOAEL
- [ ] 10 for extrapolation from animals to humans
- [x] 10 for human variability

[underlined: Modifying Factors used in MRL derivation]:

- [x] 3 for database deficiencies (inadequate information on low-dose immune system effects)

[underlined: Was a conversion used from ppm in food or water to a mg/body weight dose?] Not applicable.

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose:] Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? See worksheet for chronic-duration inhalation MRL.

[underlined: Other additional studies or pertinent information which lend support to this MRL]: There is abundant evidence for neurological and neurobehavioral effects at low exposures to tetrachloroethylene. While this evidence is primarily available from studies of inhalation exposure, effects after oral exposure are expected to be similar based on the available oral data and pharmacokinetic studies suggesting similar blood levels of parent compound after inhalation and oral exposure of humans to tetrachloroethylene (see for example, the PBPK model by Chiu and Ginsberg [2011]). Among human and animal studies of intermediate-duration oral exposure, only Chen et al. (2002) examined sensitive neurological or neurobehavioral effects. An intermediate-duration 8-week study by Chen et al. (2002) identified a LOAEL of 5 mg/kg/day (adjusted to equivalent continuous dose of 3.6 mg/kg/day based on administration on 5 days/week) for impaired nociception (increased latency to tail withdrawal from hot water and increased response latency to hot plate tests) and increased threshold for pentylenetetrazol-induced seizure initiation. PBPK modeling results reported by Chiu and Ginsberg (2011) indicate that the area under the tetrachloroethylene blood concentration-time curve for humans is about twice that of rats across a wide range continuous oral doses (0.01–1,000 mg/kg/day). Thus, the human-equivalent LOAEL dose from the study by Chen et al. (2002) is 1.8 mg/kg/day. This LOAEL is virtually identical to the human oral LOAEL of 2.3 mg/kg/day obtained by route-to-route extrapolation from the Cavalleri et al. (1994) chronic inhalation study. Because the human data provide a better basis for MRL derivation than the rat data, the chronic-duration oral MRL was applied to all exposure durations.

It should be noted that the lowest effect levels for acute- or intermediate-duration oral exposure to tetrachloroethylene were from rat and mouse studies of drinking water exposures examining immune stimulation. Seo et al. (2008a, 2012) observed enhancement of antigen-stimulated allergic responses in rats and mice exposed to estimated doses of 0, 0.0009, or 0.09 mg/kg/day (rats) and 0, 0.0025, or 0.26 mg/kg/day (mice) tetrachloroethylene administered in drinking water for 2 or 4 weeks. Little support for the observed enhancement of allergic response has been shown in other animal studies of tetrachloroethylene exposure, and few human data pertaining to immune system effects of tetrachloroethylene are available. The studies by Seo et al. (2008a, 2012) were considered for MRL derivation. However, the evidence for enhanced allergic responses after oral tetrachloroethylene exposure is limited to studies from a single laboratory using small numbers of animals (4–6 per group) and uncertain dose estimates, and support for immune system perturbation in animals or humans exposed to tetrachloroethylene is lacking. Furthermore, the effects reported by Seo and coworkers (enhanced passive and active cutaneous anaphylaxis, increased histamine release, etc.) are of uncertain toxicological and human health relevance, as it is unclear when these responses can be considered adverse. Due to the lack of supporting evidence for immune system perturbation, unclear relevance of the enhanced allergic response to humans, and uncertainty regarding when such an effect is considered adverse, these studies were not used for oral MRL derivation.

[underlined: Agency Contact (Chemical Manager)]: Rae Benedict

## Tetrachloroethylene Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Tetrachloroethylene
CAS Numbers: | 127-18-4
Date: | June 2019
Profile Status: | Final
Route: | [ ] Inhalation [x] Oral
Duration: | [ ] Acute [ ] Intermediate [x] Chronic
Graph Key: | 128 (see Figure 3-1)
Species: | Human

[underlined: Minimal Risk Level]: 0.008 [x] mg/kg/day [ ] ppm

[underlined: Reference]: Cavalleri A; Gobba F; Paltrinieri M; . 1994. Perchloroethylene exposure can induce colour vision loss. Neurosci Lett 179:162–166.7845613

Gobba F; Righi E; Fantuzzi G; . 1998. Two-year evolution of perchloroethylene-induced color-vision loss. Arch Environ Health 53:196–198.9814715

[underlined: Experimental design]: See worksheet for chronic-duration inhalation MRL.

[underlined: Effects noted in study and corresponding doses]: See worksheet for chronic-duration inhalation MRL.

[underlined: Dose and end point used for MRL derivation]:

[ ] NOAEL [ x ] LOAEL

2.3 mg/kg/day, increased Color Confusion Index (CCI), estimated by route-to-route extrapolation from continuous-equivalent inhalation exposure concentration of 1.7 ppm. The internal dose metric chosen for route-to-route extrapolation was the 24-hour AUC of the tetrachloroethylene blood concentration-time curve. While it is not certain whether the neurological effects of tetrachloroethylene result from the parent compound or one or more of its metabolites, the AUC of the tetrachloroethylene blood concentration-time curve is assumed to represent a reasonable surrogate for the internal dose of the ultimate toxicant(s). In addition, Chiu and Ginsberg (2011) showed that alternative dose metrics (based on metabolites) yielded minimal differences in route-to-route extrapolation (within 1.4-fold of the extrapolation based on blood AUC). Based on simulations of the Chiu and Ginsberg (2011) model, a continuous inhalation exposure to 1.7 ppm yields the same 24-hour AUC as a continuous oral dose of 2.3 mg/kg/day.

[underlined: Uncertainty Factors used in MRL derivation]:

- [x] 10 for use of a LOAEL
- [ ] 10 for extrapolation from animals to humans
- [x] 10 for human variability

[underlined: Modifying Factors used in MRL derivation]:

- [x] 3 for database deficiencies (inadequate information on low-dose immune system effects)

[underlined: Was a conversion used from ppm in food or water to a mg/body weight dose?] Not applicable.

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose:] Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? See worksheet for chronic-duration inhalation MRL.

[underlined: Other additional studies or pertinent information which lend support to this MRL]: The available human epidemiological studies of oral exposure to tetrachloroethylene do not provide sufficient exposure information to identify effect levels, and are thus not suitable for oral MRL derivation. The only available chronic-duration oral study of tetrachloroethylene in animals is the NCI (1977) cancer bioassay. In this study, survival was decreased at the lowest dose in both rats and mice; thus, it is also not suitable for use in deriving a chronic-duration oral MRL.

There is abundant evidence for neurological and neurobehavioral effects after chronic, low exposures to tetrachloroethylene. While this evidence is primarily available from studies of inhalation exposure, effects after oral exposure are expected to be similar based on the available oral data and pharmacokinetic studies suggesting similar blood levels of parent compound after inhalation and oral exposure of humans to tetrachloroethylene (see for example, the PBPK model by Chiu and Ginsberg [2011]). Given the lack of suitable chronic-duration oral data, and the availability of a robust PBPK model for route-to-route extrapolation, the chronic-duration MRL was derived by route-to-route extrapolation from the chronic-duration inhalation MRL using the PBPK model.

[underlined: Agency Contact (Chemical Manager)]: Rae Benedict