# 9 REFERENCES

*Not cited in text

ACGIH. 2005. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles. Atlanta, GA: Agency for Toxic Substances and Disease Registry, Division of Toxicology. Fed Regist 54(174):37618–37634.
*Agency for Toxic Substances and Disease Registry. 1996. Toxicological profile query; list of all toxicological profiles. Atlanta, GA: Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/toxpro2.html. April 17, 2006.
Agency for Toxic Substances and Disease Registry. 1997. Toxicological profile for tetrachloroethylene (update). Atlanta, GA: Agency for Toxic Substances and Disease Registry. PB98101181AS. http://www.atsdr.cdc.gov/toxprofiles/tp18.html. July 15, 2006.
AIChE. 1995. 1,1,2,2-Tetrachloroethane. C2H2Cl4. In: Physical and thermodynamic properties of pure chemicals. American Institute of Chemical Engineers, Design Institute for Physical Property Data. Philadelphia, PA: Taylor and Francis.
Altman PL, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
Amaral OC, Olivella L, Grimalt JO, . 1994. Combined solvent extraction-purge and trap method for the determination of volatile organic compounds in sediments. J Chromatogr 675(1–2):177–187.
Amin TA, Narang RS. 1985. Determination of volatile organics in sediment at nanogram-per-gram concentrations by gas chromatography. Anal Chem 57:648–651.
Amoore JE, Hautala E. 1983. Odor as an aid to chemical safety: Odor thresholds compared with threshold limit values and volatilities for 214 industrial chemicals in air and water dilution. J Appl Toxicol 3:272–290.6376602
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Andersen ME, Clewell HJ III, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
APHA. 1989a. Method 6210D. Purge and trap capillary column gas chromatography/mass spectrometric method. In: Standard methods for the examination of water and wastewater. 17th ed. Washington, DC: American Public Health Association, American Water Works Association, Water Pollution Control Federation.
APHA. 1989b. Method 6230D. Purge and trap capillary-column gas chromatographic method. In: Standard methods for the examination of water and wastewater. 17th ed. Washington, DC: American Public Health Association, American Water Works Association, Water Pollution Control Federation.
Archer WL. 1979. Other chloroethanes. In: Grayson H, Eckroth D, eds. Kirk-Othmer encyclopedia of chemical technology. 3rd ed. Vol. 5. New York, NY: John Wiley and Sons, 722–742.
Arthur D. Little, Inc. 1983. Cell transformation assays of 11 chlorinated hydrocarbon analogs (final report). ICAIR work assignment no. 10. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0509392.
Ashley DL, Bonin MA, Cardinalis FL, . 1992. Determining volatile organic compounds in human blood from a large sample population by using purge and trap gas chromatography/mass spectrometry. Anal Chem 64:1021–1029.1590585
ASTER. 1995. ASTER ecotoxicity profile. Duluth, MN: Assessment Tools for the Evaluation of Risk (ASTER). U.S. Environmental Protection Agency. Environmental Research Laboratory. October 11, 1995.
Atkinson R. 1987. A structure-activity relationship for the estimation of rate constants for gas-phase reaction of OH radicals with organic compounds. Int J Chem Kinet 19:799–828.
Atlas E, Schauffler S. 1991. Analysis of alkyl nitrates and selected halocarbons in the ambient atmosphere using a charcoal preconcentration technique. Environ Sci Technol 25(1):61–67.
Barnes D, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Barrows ME, Petrocelli SR, Macek KJ, . 1980. Bioconcentration and elimination of selected water pollutants by bluegill sunfish (Lepomis macrochirus). In: Haque R, ed. Dynamics, exposure, and hazard assessment of toxic chemicals. Ann Arbor, MI: Ann Arbor Science, 379–392.
Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag, 3–7.
Bi X, Sheng G, Feng Y, . 2005. Gas- and particulate-phase specific tracer and toxic organic compounds in environmental tobacco smoke. Chemosphere 61(10):1512–1522.15975627
*Bollman JL, Mann FC. 1931. Experimentally produced lesions of the liver. Ann Intern Med 5:699–712.
Bonin MA, Ashley DL, Cardinali FL, . 1992. Importance of enhanced mass resolution in removing interferences when measuring volatile organic compounds in human blood by using purge-and-trap gas chromatography/mass spectrometry. J Am Soc Mass Spectrom 3:831–841.24234706
Borisover MD, Graber ER. 1997. Specific interactions of organic compounds with soil; organic carbon. Chemosphere 34(8):1761–1776.
Bouwer EJ, McCarty PL. 1983. Transformations of 1- and 2-carbon halogenated aliphatic organic compounds under methanogenic conditions. Appl Environ Microbiol 45:1286–1294.6859849
Breimer DD, Ketelaars HCJ, Van Rossum JM. 1974. Gas chromatographic determination of chloral hydrate, trichloroethanol and trichloroacetic acid in blood and in urine employing head-space analysis. J Chromatogr 88:55–63.
Brem H, Stein AB, Rosenkranz HS. 1974. The mutagenicity and DNA-modifying effect of haloalkanes. Cancer Res 34:2576–2579.4607208
Brodzinsky R, Singh HB. 1982. Volatile organic chemicals in the atmosphere: An assessment of available data. Menlo Park, CA: Atmospheric Science Center, SRI International, 99–100.
Bull RJ, Sanchez IM, Nelson MA, . 1990. Liver tumor induction in B6C3F1 mice by dichloroacetate and trichloroacetate. Toxicology 63:341–359.2219130
Burton DT, Dilorenzo JL, Shedd TR, . 2002. Aquatic hazard assessment of a contaminated surficial aquifer discharge into the Bush River, Maryland (USA). Water Air Soil Pollut 139(1–4):159–182.
Callen DF, Wolf CR, Philpot RM. 1980. Cytochrome P-450 mediated genetic activity and cytotoxicity of seven halogenated aliphatic hydrocarbons in Saccharomyces cerevisiae. Mutat Res 77:55–63.6767185
Carpenter CP, Smyth HF, Pozzani UC. 1949. The assay of acute vapor toxicity and the grading and interpretation of results on 96 chemical compounds. J Ind Hyg Tox 31:343–346.
Casciola LAF, Ivanetich KM. 1984. Metabolism of chloroethanes by rat liver nuclear cytochrome P-450. Carcinogenesis 5:543–548.6722974
CEPA. 1993. 1,1,2,2,-Tetrachlorethane: Priority substances list assessment report. Ottawa, Canada: Canada Environmental Protection Act, Priority Substance List Assessment Report.
Cervini-Silva J. 2003. Linear free-energy relationship analysis of the fate of chlorinated 1- and 2-carbon compounds by redox-manipulated smectite clay minerals. Environ Toxicol Chem 22(10):2298–2305.14551992
Chai M, Pawliszyn J. 1995. Analysis of environmental air samples by solid-phase microextraction and gas chromatography/ion trap mass spectrometry. Environ Sci Technol 29(3):693–701.22200278
Charbonneau M, Greselin E, Brodeur J, . 1991. Influence of acetone on the severity of the liver injury induced by haloalkane mixtures. Can J Physiol Pharmacol 69:1901–1907.1802361
ChemID. 2004. 1,1,2,2-Tetrachloroethane. ChemIDplus. National Library of Medicine. http://chem.sis.nlm.nih.gov/chemidplus/cmplxqry.html. March 06, 2006.
Chen C, Puhakka JA, Ferguson JF. 1996. Transformations of 1,1,2,2-tetrachloroethane under methanogenic conditions. Environ Sci Technol 30:542–547.
Chen XM, Dallas CE, Muralidhara S, . 1993. Analysis of volatile C_2_ haloethanes and haloethenes in tissues: Sample preparation and extraction. J Chromatogr 612:199–208.8468377
*Chieruttini ME, Franklin CS. 1976. The toxicology of tetrachloroethanes. Br J Pharmacol 57(3):421.
Chiou CT, Peters LJ, Freed VH. 1979. A physical concept of soil-water equilibria for nonionic organic compounds. Science 206:831–832.17820762
Christensen JM, Rasmussen K, Koppen B. 1988. Automatic headspace gas chromatographic method for the simultaneous determination of trichloroethylene and metabolites in blood and urine. J Chromatogr 442:317–323.3417822
Chu W, Chan KH. 2000. The predication of partitioning coefficients for chemicals causing environmental concern. Sci Total Environ 248:1–10.10807037
Class T, Ballschmiter K. 1986. Chemistry of organic traces in air. VI: Distribution of chlorinated Cl-C4 hydrocarbons in air over the northern and southern Atlantic Ocean. Chemosphere 15:413–427.
Class T, Ballschmiter K. 1987. Global baseline pollution studies. X. Atmospheric halocarbons: Global budget estimations for tetrachloroethene, 1,2-dichloroethane, 1,1,1,2-tetrachloroethane, hexachloroethane, and hexachlorobutadiene. Estimation of the hydroxyl radical concentrations in the troposphere of the northern and southern hemispheres. Fresenius’ Z Anal Chem 327:198–204.
Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Colacci A, Grilli S, Lattanzi G, . 1987. The covalent binding of 1,1,2,2-tetrachloroethane to macromolecules of rat and mouse organs. Teratog Carcinog Mutagen 7:465–474.2893460
Colacci A, Perocco P, Bartoli S, . 1992. Initiating activity of 1,1,2,2-tetrachlorethane in two-stage BALB/c 3T3 cell transformation. Cancer Lett 64:145–153.1611598
Colacci A, Perocco P, Vaccari M, . 1990. In vitro transformation of BALB/c 3T3 cells by 1,1,2,2-tetrachloroethane. Jpn J Cancer Res 81:786–792.2118891
Colacci A, Vaccari M, Perocco P, . 1996. Enhancement of BALB/c 3T3 cells transformation by 1,2-dibromoethane promoting effect. Carcinogenesis 17(2):225–231.8625443
Cole RH, Frederick RE, Healy RP, . 1984. Preliminary findings of the priority pollutant monitoring project of the Nationwide Urban Runoff Program. Journal WPCF 56(7):898–908.
Comba ME, Kaiser KLE. 1983. Determination of volatile contaminants at the ng 1-1 level in water by capillary gas chromatography with electron capture detection. Int J Environ Anal Chem 16:17–31.
Cooper WJ, Mehran M, Riusech DJ, . 1987. Abiotic transformations of halogenated organics. 1. Elimination reaction of 1,1,2,2-tetrachloroethane and formation of 1,1,2-trichloroethene. Environ Sci Technol 21:1112–1114.
Cottalasso D, Bellocchio A, Domenicotti C, . 1998. 1,1,2,2-Tetrachloroethane-induced early decrease of dolichol levels in rat liver microsomes and golgi apparatus. J Toxicol Environ Health A 54:133–144.9652549
Cox RD. 1983. Sample collection and analytical techniques for volatile organics in air. In: Measurement and monitoring of non-criteria (toxic) contaminants in air. Pittsburgh, PA: Air Pollution Control Association, 101–112.
Coyer HA. 1944. Tetrachloroethane poisoning. Ind Med 13:230–233.
Cramer PH, Boggess KE, Hosenfeld JM, . 1988. Determination of organic chemicals in human whole blood: Preliminary method development for volatile organics. Bull Environ Contam Toxicol 40:612–618.3370355
Crebelli R, Benigni R, Franekic J, . 1988. Induction of chromosome malsegregation by halogenated organic solvents in Aspergillus nidulans: Unspecific or specific mechanism? Mutat Res 201:401–411.3050490
Daft JL. 1989. Determination of fumigants and related chemicals in fatty and nonfatty foods. J Agric Food Chem 37:560–564.
Daniel FB, DeAngelo AB, Stober JA, . 1992. Hepatocarcinogenicity of chloral hydrate, 2-chloroacetaldehyde, and dichloroacetic acid in male B6C3F1 mouse. Fundam Appl Toxicol 19:159–168.1516771
DeAngelo AB, Daniel FB, Most BM, . 1996. The carcinogenicity of dichloroacetic acid in the male Fischer 344 rat. Toxicology 114:207–221.8980710
DeAngelo AB, Daniel FB, Stober JA, . 1991. The carcinogenicity of dichloroacetic acid in the male B6C3F1 mouse. Fundam Appl Toxicol 16:337–347.2055364
DeAngelo AB, George MH, House DE. 1999. Hepatocarcinogenicity in the male B6C3F1 mouse following a life-time exposure to dichloroacetic acid in the drinking water: Dose-response determination and modes of action. J Toxicol Environ Health 58:485–507.
DeAngelo AB, Herren-Freund S, Perreira MA, . 1986. Species sensitivity of the induction of peroxisome proliferation by trichloroethylene and its metabolites. Toxicologist 6:113.
Deguchi T. 1972. [A fundamental study of the threshold limit values for solvent mixtures in the air--Effects of single and mixed chlorinated hydrocarbons upon the level of serum transaminases in rats.] Osaka City Med J 21:187–209. (Japanese)
DeMarini DM, Brooks HG. 1992. Induction of phophage lambda by chlorinated organics: Detection of some single-species/single-site carcinogens. Environ Mol Mutagen 19:98–111.1531793
DOT. 2005. Purpose and use of hazardous materials table. List of marine pollutants. U.S. Department of Transportation. Code of Federal Regulations. 49 CFR 172.101, Appendix B. http://a257.g.akamaitech.net/7/257/2422/09nov20051500/edocket.access.gpo.gov/cfr_2005/octqtr/pdf/49cfr172.101.pdf. January 08, 2008.
Dow. 1944. The toxicity of tetrachloroethane. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0517047.
Driscoll NM, Duffy H, Pappas S, . 1987. Analysis for purgeable organics in water by capillary BC/PID-ElCD. J Chromatogr Sci 25:369–375.
Ellenhorn MJ, Schonwald S, Ordog G, . 1997. 1,1,2,2-Tetrachloroethane. Ellenhorn’s medical toxicology: Diagnosis and treatment of human poisoning. 2nd ed. Baltimore, MD: Williams and Wilkins, 1436–1440.
Elliott JM. 1933. Report of a fatal case of poisoning by tetrachloroethane. J Army Med Corp 60:373–374.
EPA. 1977. Monitoring to detect previously unrecognized pollutants in surface waters. Appendix: Organic analysis data. Washington, DC: U.S. Environmental Protection Agency. EPA560677015. (Appendix: EPA560677OlSA).
EPA. 1979. Water-related environmental fate of 129 priority pollutants-Volume III. Washington, DC: U.S. Environmental Protection Agency. EPA440479029B.
EPA. 1980. Survey of the Huntington and Philadelphia river water supplies for purgeable organic contaminants. Annapolis, MD: U.S. Environmental Protection Agency, EPA903981003.
EPA. 1982a. Method 624. Purgeables. In: Test methods. Methods for organic chemical analysis of municipal and industrial wastewater. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory.
EPA. 1982b. Method 5030. Purge-and-trap method. In: Test methods for evaluating solid waste. Physical/Chemical methods. SW-846. 2nd ed. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
EPA. 1984a. Method 601. Purgeable halocarbons. In: Guidelines establishing test procedures for the analysis of pollutants under the Clean Water Act; final rule and interim final rule and proposed rule. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136.
EPA. 1984b. Method T01. Method for the determination of volatile organic compounds in ambient air using Tenaz adsorption and gas chromatography/ mass spectrometry (GC/MS). In: Compendium of methods for determination of toxic organic compounds in ambient air. Research Triangle Park, NC: U.S. Environmental Protection Agency, Environmental Monitoring Systems Laboratory, Office of Research and Development. EPA600484041.
EPA. 1984c. Compendium method T0-14. The determination of volatile organic compounds (VOCs) in ambient air using Summa passivated canister sampling and gas chromatographic analysis. In: Compendium of methods for determination of toxic organic compounds in ambient air. Research Triangle Park, NC: U.S. Environmental Protection Agency, Environmental Monitoring Systems Laboratory, Office of Research and Development. EPA600484041. http://www.epa.gov/ttn/amtic/files/ambient/airtox/to-14ar.pdf. May 10, 2006.
EPA. 1986a. Method 8240. Gas chromatography/mass spectrometry for volatile organics. In: Test methods for evaluating solid waste: Volume 1B: Laboratory manual physical/chemical methods. SW-846. 3rd ed. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
EPA. 1986b. Method 8010. Halogenated volatile organics. In: Test methods for evaluating solid waste. Volume 1B: Laboratory manual physical/chemical methods. SW-846. 3rd ed. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
EPA. 1986c. Method 524.1. Volatile organic compounds in water by purge and trap gas chromatography/mass spectrometry. In: Methods for the determination of organic compounds in finished drinking water and raw source water. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory.
EPA. 1986d. Method 524.2. Volatile organic compounds in water by purge and trap capillary column gas chromatography/mass spectrometry. In: Methods for the determination of organic compounds in finished drinking water and raw source water. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory.
EPA. 1987. Statement of work for organic analysis: multimedia, multiconcentration. Washington, DC: U.S. Environmental Protection Agency, U.S. EPA Contract Laboratory Program.
EPA. 1988a. Method 502.1. Volatile halogenated organic compounds in water by purge and trap gas chromatography. In: Methods for the determination of organic compounds in drinking water. Cincinnati OH: U.S. Environmental Protection Agency, Environmental Monitoring Systems Laboratory, Office of Research and Development. Revision 2.0. EPA600488039.
EPA. 1988b. Method 502.2. Volatile organic compounds in water by purge and trap capillary column gas chromatography with photoionization and electrolytic conductivity detectors in series. In: Methods for the determination of organic compounds in drinking water. Cincinnati OH: U.S. Environmental Protection Agency, Environmental Monitoring Systems Laboratory, Office of Research and Development. Revision 2.0. EPA600488039.
EPA. 1988c. National ambient volatile organic compounds (VOCs) data base update. Research Triangle Park, NC: U.S. Environmental Protection Agency, Atmospheric Sciences Research Laboratory. EPA600388010a.
EPA. 1989. Methods 508, 501.1, 502.2. Methods for the determination of organic compounds in drinking water. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600484039.
EPA. 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA600890066A.
EPA. 1995. Toxic chemical release inventory reporting Form R and instructions. Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. EPA745K95051.
EPA. 1996a. Method 8260B: Volatile organic compounds by gas chromatography/mass spectrometry (GC/MS). In: SW-846 online: Test methods for evaluating solid waste, physical/chemical methods. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste. http://www.nemi.gov. April 3, 2006.
EPA. 1996b. Method 8021B: Aromatic and halogenated volatiles by gas chromatography using photoionization and/or electrolytic conductivity detectors. In: SW-846 online: Test methods for evaluating solid waste, physical/chemical methods. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste. http://www.epa.gov/epaoswer/hazwaste/test/pdfs/8021b.pdf. April 05, 2006.
EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R96012.
EPA. 2000. Benchmark dose technical guidance document [external review draft]. EPA630R00001. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/backgr-d.htm. August 1, 2006.
EPA. 2001a. Method 1624. Volatile organic compounds by isotope dilution GC/MS. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR Part 136, Appendix A, 275–287.
EPA. 2001b. Unregulated contaminant monitoring program. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/safewater/ucmr/ucm_rounds_1-2.html. March 25, 2006.
EPA. 2002. Child-specific exposure factors handbook. Washington, DC: U.S. Environmental Protection Agency, National Center for Environmental Assessment, Office of Research and Development. EPA600P00002B.
EPA. 2003. National primary drinking water standards. Washington, DC: U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water. EPA816F03016. http://www.epa.gov/safewater/mcl.html. March 07, 2006.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. Office of Environmental Information. EPA260B05001.
EPA. 2006i. 2006 Edition of the drinking water standards and health advisories. Washington, DC: Office of Water, U.S. Environmental Protection Agency. EPA822R06013. http://www.epa.gov/waterscience/criteria/drinking/dwstandards.pdf. April 11, 2007.
EPA. 2006h. Acute Exposure Guideline Levels (AEGLs) Washington, DC: Office of Pollution Prevention and Toxics. U.S. Environmental Protection Agency. http://www.epa.gov/oppt/aegl/chemlist.htm. March 14, 2006.
EPA. 2006b. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. http://a257.g.akamaitech.net/7/257/2422/22jul20061500/edocket.access.gpo.gov/cfr_2006/julqtr/pdf/40cfr302.4.pdf. January 08, 2008.
EPA. 2006a. Hazardous air pollutants. Clean Air Act. U.S. Environmental Protection Agency. United States Code. 42 USC 7412. http://www.epa.gov/ttn/atw/orig189.html. March 07, 2006.
EPA. 2006k. Identification and listing of hazardous waste. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261, Appendix VIII. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. March 08, 2006.
EPA. 2006j. National recommended water quality criteria. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Office of Science and Technology. http://www.epa.gov/waterscience/criteria/nrwqc-2006.pdf. January 08, 2008.
EPA. 2006c. Toxic chemical release reporting: Community right-to-know. Chemicals and chemical categories to which this part applies. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65. http://a257.g.akamaitech.net/7/257/2422/22jul20061500/edocket.access.gpo.gov/cfr_2006/julqtr/pdf/40cfr372.65.pdf. January 08, 2008.
EPA. 2006d. RCRA orientation manual 2006; Resource Conservation and Recovery Act. U.S. Environmental Protection Agency. http://www.epa.gov/epaoswer/general/orientat/. August 16, 2006.
EPA. 2006e. Protection of the environment: Land disposal restrictions. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268. http://ecfr.gpoaccess.gov/cgi/t/text/text-idx?c=ecfr&sid=d85c2f33b4eb3198d0bb904161bde684&rgn=div5&view=text&node=40:26.0.1.1.3&idno=40. August 16, 2006.
EPA. 2006f. 1,1,2,2-Tetrachloroethane. Modernized STORET system: Regular results by geographic location (stormodb): Characteristic search by CAS number. U.S. Environmental Protection Agency. http://www.epa.gov/storet/dbtop.html. April 06, 2006.
EPA. 2006g. Water quality standards. Toxics criteria for those states not complying with Clean Water Act section 303(c)(2)(B). U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 131.36. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. March 08, 2006.
Eriksson C, Brittebo EB. 1991. Epithelial binding of 1,1,2,2-tetrachloroethane in the respiratory and upper alimentary tract. Arch Toxicol 65:10–14.2043045
FDA. 2005a. Beverages. Bottled water. Code of Federal Regulations. 21 CFR 165.110. U.S. Food and Drug Administration. http://a257.g.akamaitech.net/7/257/2422/01apr20051500/edocket.access.gpo.gov/cfr_2005/aprqtr/pdf/21cfr165.110.pdf. January 08, 2008.
FDA. 2005b. Total diet study. Washington, DC: U.S. Food and Drug Administration, Center for Food Safety and Applied Nutrition. http://www.cfsan.fda.gov/~comm/tds-toc.html. March 18, 2006.
FEDRIP. 2006. 1,1,2,2 Tetrachloroethane. Federal Research in Progress database. Springfield, VA: National Technical Information Service.
Ferguson JF, Pietari JM. 2000. Anaerobic transformations and bioremediation of chlorinated solvents. Environ Pollut 107(2):209–215.15092997
Fisher J, Mahle D, Bankston L, . 1997. Lactational transfer of volatile chemicals in breast milk. Am Ind Hyg Assoc J 58(6):425–431.9183837
Fomon SJ. 1966. Body composition of the infant: Part I: The male reference infant. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
Forbes G. 1943. Tetrachloroethane poisoning. Br Med J 1:348–350.20784738
Franke C, Studinger G, Berger G, . 1994. The assessment of bioaccumulation. Chemosphere 29(7):1501–1514.
Galloway SM, Armstrong MJ, Reuben C, . 1987. Chromosome aberrations and sister chromatid exchange in Chinese hamster ovary cells: Evaluations of 108 chemicals. Environ Mol Mutagen 10:1–175.3319609
Gargas ML, Andersen ME. 1989. Determining kinetic constants of chlorinated ethane metabolism in the rat from rates of exhalation. Toxicol Appl Pharmacol 99:344–353.2734795
Gargas ML, Burgess RJ, Voisard DE, . 1989. Partition coefficients of low-molecular-weight volatile chemicals in various liquids and tissues. Toxicol Appl Pharmacol 98:87–99.2929023
Gianti SJ Jr, Harkov R, Bozzelli JW. 1984. Monitoring volatile organic compounds at hazardous and sanitary landfills in New Jersey. Presented 77th Annual Meeting of the Air Pollution Control Association, Paper No. 84-3.7, June 24-29, San Francisco, CA. Pittsburgh, PA: Air Pollution Control Association.
Ginsberg G, Hattis D, Sonawane B, . 2002. Evaluation of child/adult pharmacokinetic differences from a database derived from the therapeutic drug literature. Toxicol Sci 66:185–200.11896285
Ginsberg G, Hattis D, Sonawane B. 2004. Incorporating pharmacokinetic differences between children and adults in assessing children’s risk to environmental toxicants. Toxicol Appl Pharmacol 198:164–183.15236952
Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
Gobbato F, Bobbio G. 1968. [Investigation of the cardiovascular function in 75 industrial workers employed in the production of tetrachloroethane, trichloroethylene and perchloroethylene.] Securitias 53:43–63. (Italian)
Gohlke R, Schmidt P. 1972. [Subacute action of low concentrations of chlorinated ethanes with and without additional ethanol treatment in the rat.] Int Arch Arbeitsmed 30:299–312. (German)4675411
Gohlke R, Schmidt P, Bahmann H. 1977. [1,1,2,2-Tetrachloroethane and heat stress in animal experiment. Morphological results.] Z Gesamte Hyg IHRE Grenzgeb 20:278–282. (German)
Goldfrank LR, Flomenbaum NE, Lewin NA, . 2002. Hydrocarbons. In: Goldfrank’s toxicologic emergencies. New York, NY: McGraw Hill, 1303–1322.
Guengerich FP, Kim D-H, Iwasaki M. 1991. Role of human cytochrome P-450 IIE1 in the oxidation of many low molecular weight cancer suspects. Chem Res Toxicol 4:168–179.1664256
Guidotti M, Onorati B, Lucarelli E, . 2001. Determination of chlorinated solvents in exhaled air, urine, and blood of subjects exposed in the workplace using SPME and GC-MS. Am Clin Lab 20(4):23–26.
Gupta KC, Ulsamer AG, Gammage R. 1984. Volatile organic compounds in residential air: Levels, sources and toxicity. Proc APCA Annual Meeting 77:1–9.
Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Haag WR, Mill T. 1988. Effect of a subsurface sediment on hydrolysis of haloalkanes and epoxides. Environ Sci Technol 22:658–663.
Haddad LM, Shannon MW, Winchester JF. 1998. Chlorinated hydrocarbons. In: Clinical management of poisoning and drug overdose. Philadelphia, PA: WB Saunders Company, 931–939.
Hallen RT, Pyne JW Jr, Molton PM. 1986. Transformation of chlorinated ethenes and ethanes by anaerobic microorganisms. In: American Chemical Society Division of Environmental Chemistry: 192nd National Meeting, Anaheim, California, September 7-12, 1986. Washington, DC: American Chemical Society, 344–346.
Halpert J. 1981. Covalent modification of lysine during the suicide inactivation of rat liver cytochrome P-450 by chloramphenicol. Biochem Pharmacol 30:875–881.6788044
Halpert J. 1982. Cytochrome P-450 dependent covalent binding of 1,1,2,2-tetrachloroethane in vitro. Drug Metab Dispos 10:465–468.6128194
Halpert J, Neal RA. 1981. Cytochrome P-450 metabolism of 1,1,2,2-tetrachloroethane to dichloroacetic acid in vitro. Biochem Pharmacol 30:1366–1368.7271831
Halpert JR, Balfour C, Miller NE, . 1986. Dichloromethyl compounds as mechanism-based inactivators of rat liver cytochromes P-450 in vitro. Mol Pharmacol 30:19–24.3724741
Hamilton A. 1917. Military medicine and surgery. J Am Med Assoc 69:2037–2039.
Hanley TR, Quast JF, Schumann AM. 1988. The metabolism and hepatic macromolecular interactions of 1,1,2,2-tetrachloroethane (TCE) in mice and rats. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0514187.
Hansch C, Leo A, Hoekman D. 1995. 1,1,2,2-Tetrachloroethane. In: Exploring QSAR hydrophobic, electronic, and steric constants. Washington, DC: American Chemical Society, 4.
Harkov R, Katz R, Bozzelli J, . 1981. Toxic and carcinogenic air pollutants in New Jersey volatile organic substances. In: McGovern JJ, ed. Proceedings from International Technical Conference Toxic Air Contamination, 1980. Pittsburgh, PA: Air Pollution Control Association, 104–119.
Harkov R, Kebbekus B, Bozzelli JW, . 1983. Measurement of selected volatile organic compounds at three locations in New Jersey during the summer season. JAPCA 33:1177–1183.
Harkov R, Kebbekus B, Bozzelli JW. 1987. Volatile organic compounds at urban sites in New Jersey. In: Lioy PJ, Daisey JM, eds. Toxic air pollutants. Chelsea, MI: Lewis Publishers, 69–88.
Harte J, Holdren C, Schneider R, . 1991. Toxics A to Z: A guide to everyday pollution hazards. Berkeley, CA: University of California Press, 303–305, 413–415, 418–422, 430–433.
Hartwell TD, Pellizzari ED, Penritt RL, . 1987. Results from the total exposure assessment methodology (TEAM) study in selected communities in northern and southern California. Atmos Environ 21:1995–2004.
Haworth S, Lawlor T, Mortelmans K, . 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen 5:3–142.
HazDat. 2008. 1,1,2,2-tetrachloroethane. HazDat Database: ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA: Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/hazdat.html. June 5, 2008.
Hemmings HC Jr, Akabas MH, Goldstein PA, . 2005. Emerging molecular mechanisms of general anesthetic action. Trends Pharmacol Sci 26(10):503–510.16126282
Hepple RA. 1927. An unusual case of poisoning. J Army Med Corp 49:442–445.
Herren-Freund SL, Pereira MA, Khoury DK, . 1987. The carcinogenicity of trichloroethylene and its metabolites, trichloroacetic acid and dichloroacetic acid, in mouse liver. Toxicol Appl Pharm 90:183–189.
Hiatt MH. 1983. Determination of volatile organic compounds in fish samples by vacuum distillation and fused silica capillary gas chromatography/mass spectrometry. Anal Chem 55:506–516.6846846
Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
*Horiguchi S, Morioka S, Utsunomiya T, . 1964. A survey of the actual conditions of artificial pearl factories with special reference to the work using tetrachloroethane. Jpn J Ind Health 6:251–256.
Horiuchi K, Horiguchi S, Hashimoto K, . 1962. Studies on the industrial tetrachloroethane poisoning. Osaka City Medical J 8:29–38.
Horvath AL, Getzen FW, Maczynska Z. 1999. IUPAC-NIST solubility data series 67. Halogenated ethanes and ethenes with water. J Phys Chem Ref Data 28:395–627.
Horvath M, Frantik E. 1973. To the relative sensitivity of nervous functions and behavior to nonspecific effects of foreign substances. Activ Nerv Super 15:25–27.
HSDB. 1996. Online. Hazardous Substance Data Bank. National Library of Medicine, Bethesda, MD.
HSDB. 2006. 1,1,2,2-tetrachloroethane. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. March 30, 2006.
IARC. 1979. 1,1,2,2-Tetrachloroethane. IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans: Some halogenated hydrocarbons. Lyon, France: International Agency for Research on Cancer, World Health Organization 20:477–489.
IARC. 2004. Overall evaluations of carcinogenicity to humans: As evaluated in IARC Monographs volumes 1-82 (at total of 900 agents, mixtures and exposures). Lyon, France: International Agency for Research on Cancer. http://www-cie.iarc.fr/monoeval/crthall.html. March 08, 2006.
Ikeda M, Ohtsuji H. 1972. Comparative study of the excretion of Fujiwara reaction-positive substances in urine of humans and rodents given trichloro-or tetrachloro-derivatives of ethane and ethylene. Br J Ind Med 29:99–184.5060252
IRIS. 2006. 1,1,2,2 Tetrachloroethane. Washington, DC: Integrated Risk Information System, U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/index.html. March 08, 2006.
IUR. 2002. Inventory update rule. Toxic Substance Control Act (TSCA) Inventory Update Database. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/opt/uiru/iur02/index.htm. March 22, 2006.
Jafvert CT, Wolfe NL. 1987. Degradation of selected halogenated ethanes in anoxic sediment-water systems. Environ Toxicol Chem 6:827–837.
Jakobson I, Wahlberg JE, Holmberg B, . 1982. Uptake via the blood and elimination of 10 organic solvents following epicutaneous exposure of anesthetized guinea pigs. Toxicol Appl Pharmacol 63:181–187.7089968
Jeney E, Bartha F, Kondor L, . 1957. [Prevention of industrial tetrachloroethane intoxication--Part III.] Egeszsegtudomany 1:155–164. (Hungarian)
Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
Johansson I, Ekstrom G, Scholte B, . 1988. Ethanol-, fasting- and acetone-inducible cytochromes P-450 in rat liver. Biochemistry 27:1925–1934.3378038
*Kanada M, Miyagawa M, Sato M, . 1994. Neurochemical profile of effects of 28 neurotoxic chemicals on the central nervous system in rats (1). Effects of oral administration on brain contents of biogenic amines and metabolites. Ind Health 32:145–164.7698903
Khourey CJ, Mohr ET, Gifford G, . 1984. Purgeable organic compounds in northeast Ohio groundwater. Trace Subst Environ Health 18:397–403.
Kincannon DF, Weinert A, Padorr R, . 1983. Predicting treatability of multiple organic priority pollutant wastewater from single-pollutant treatability studies. In: Bell MR, ed. Proceedings 37th Industrial Waste Conference. Ann Arbor, MI: Ann Arbor Science, 641–650.
*Kitchin KT, Brown JL, Kulkarni AP. 1992. Predictive assay for rodent carcinogenicity using in vivo biochemical parameters: Operation characteristics and complementarity. Mutat Res 266(2):253–272.1373835
Klaassen, CD. 1996. Casarett & Doull’s toxicology: The basic science of poisons. 5th ed. New York, NY: McGraw-Hill, 750–751.
Klečka GM, Gonsior SJ. 1983. Nonenzymatic reductive dechlorination of chlorinated methane and ethanes in aqueous solution. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8. OTS206368.
Koelsch F. 1915. Industrial poisonings by celluloid varnishes in the airplane industry. Muench Medizin Wochensch 62:1567–1569.
Koizumi A, Kumai M, Ikeda M. 1982. Enzymatic formation of an olefin in the metabolism of 1,1,2,2-tetrachloroethane: An in vitro study. Bull Environ Contam Toxicol 29:562–565.7150804
Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29:4430–4433.2350547
Konasewich D, Traversy W, Zar H. 1978. Great Lakes water quality status report on organic and heavy metal contaminants in the Lakes Erie, Michigan, Huron, and Superior basins. Windsor, Ontario: Great Lakes Water Quality Board, 26–27, 112.
Konietzko H. 1984. Chlorinated ethanes: Sources, distribution, environmental impact, and health effects. Hazard Assessment of Chemicals Current Developments 3:401–448.
Koppel C, Armdt I, Arendt U, . 1985. Acute tetrachloroethylene poisonings: Blood elimination kinetics during hyperventilation therapy. Clin Toxicol 23:103–115.
Koppen B, Dalgaard L, Christensen JM. 1988. Determination of trichloroethylene metabolites in rat liver homogenate using headspace gas chromatography. J Chromatog 442:325–332.3417823
Krill RM, Sonzogni WC. 1986. Chemical monitoring of Wisconsin’s groundwater. J Am Water Works Assoc 78:70–75.
Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Andersen ME, Clewell HJ III, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kronevi T, Wahlberg JE, Holmberg B. 1981. Skin pathology following epicutaneous exposure to seven organic solvents. Int J Tissue React 3:21–30.7026421
Krost KJ, Pellizzari ED, Walburn SG, . 1982. Collection and analysis of hazardous organic emissions. Anal Chem 54:810–817.
Kulinskaya IL, Verlinskaya RV. 1972. [Comparative effect of low concentration of di-, tetra- and pentachloroethane on the blood acetylcholine system.] Gig Tr Prof Zabol 16:56–58. (Russian)
Laass W. 1973a. [Suitability of castor oil treating acute oral poisonings with organic solvents. Pharmazie 28:684–685. (German)
Laass W. 1973b. [Animal experimental studies on the suitability of mineral oil in acute oral poisoning with organic solvents.] Pharmazie 28:65–66. (German)4714246
Laass W. 1974a. [Animal studies on the action of milk in acute oral poisonings with organic solvents.] Pharmazie 29:729. (German)
Laass W. 1974b. [Suitability of using activated charcoal for the treatment of acute oral poisoning with organic solvents.] Pharmazie 29:728–729. (German)4438419
LaRegina J, Bozzelli JW, Harkov R, . 1986. Volatile organic compounds at hazardous waste sites and a sanitary landfill in New Jersey. An up-to-date review of the present situation. Environ Prog 5:18–27.
Lazarew NW. 1929. [The narcotic effect of the vapors of the chloride derivatives of methane, ethane and ethylene.] Arch Exp Path Pharmakol 141:19–24. (German)
Lee MD, Mazierski PF, Buchanan RJ, . 1995. Intrinsic in situ anaerobic biodegradation of chlorinated solvents at an industrial landfill. In: Hinchee RE, ed. Intrinsic bioremediation. 3rd ed. Columbus, OH: Battelle Press, 205–222.
Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Lehmann KB. 1911. [Experimental studies on the influence of technology and hygienically important gases and vapors on the organism (XVI-XXIII)-Chlorinated aliphatic hydrocarbons and considerations on the one-stage and two-stage toxicity of volatile products.] Arch Hyg 74:1–3,24–28,46–60. (German)
Lehmann KB, Schmidt-Kehl L. 1936. [Study of the 13 most important chlorohydrocarbons from the standpoint of industrial hygienics.] Arch Hyg 116:132–200. (German)
Leighton DT Jr, Calo JM. 1981. Distribution coefficients of chlorinated hydrocarbons in dilute air-water systems for groundwater contamination applications. J Chem Eng Data 26:382–385.
Lesage S. 1991. Characterization of groundwater contaminants using dynamic thermal stripping and adsorption/ thermal desorption - GC-MS. Fresenius J Anal Chem 339:516–527.
Leung H-W. 1993. Physiologically-based pharmacokinetic modeling. In: Ballentyne B, Marrs T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Lewis RJ. 2001. Hawley’s condensed chemical dictionary. 14th ed. New York, NY: John Wiley & Sons, Inc., 1079.
Lide DR, ed. 2005. CRC handbook of chemistry and physics. 86th ed. Boca Raton FL: CRC Press, 3-470, 3-471.
Lilliman B. 1949. Suggested mechanism of poisoning by liquid tetrachloroethane. Analyst 74:510–511.
Lioy PJ, Daisey JM, Greenberg A, . 1985. A major wintertime (1983) pollution episode in northern New Jersey: Analysis of the accumulation and spatial distribution of inhalable particulate matter, extractable organic matter and other species. Atmos Environ 19:429–436.
Livingston, AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
Lobo-Mendonca R. 1963. Tetrachloroethane - A survey. Br J Ind Med 20:51–56.
Lopez-Avila V, Heath N, Hu A. 1987. Determination of purgeable halocarbons and aromatics by photoionization and Hall electrolytic conductivity detectors connected in series. J Chromatog Sci 25:356–363.
Lorah MM, Olsen LD. 1999a. Natural attenuation of chlorinated volatile organic compounds in a freshwater tidal wetland: Field evidence of anaerobic biodegradation. Water Resour Res 35(12):3811–3827.
Lorah MM, Olsen LD. 1999b. Degradation of 1,1,2,2-tetrachloroethane in a freshwater tidal wetland: Fields and laboratory evidence. Environ Sci Technol 33:227–234.
Lorah MM, Voytek MA. 2004. Degradation of 1,1,2,2-tetrachloroethane and accumulation of vinyl chloride in wetland sediment microcosms and in situ porewater: Biogeochemical controls and associations with microbial communities. J Contam Hydrol 70(1–2):117–145.15068871
Mackay D, Shiu WY. 1981. A critical review of Henry’s Law constants for chemicals of environmental interest. J Phys Chem Ref Data 10(4):1175–1199.
Mant AK. 1953. Acute tetrachlorethane poisoning. A report on two fatal cases. Br Med J 655–656.13032437
Matz G, Kesners P. 1993. Spray and trap method for water analysis by thermal desorption gas chromatography/mass spectrometry in field applications. Anal Chem 65:2366–2371.
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
Melton RG, Coleman WE, Slater RW . 1981. Comparison of Grob closed-loop stripping analysis with other trace organic methods. In: Keith LH, ed. Advances in the identification & analysis of organic pollutants in water. Ann Arbor, MI: Ann Arbor Science, 597–673.
Meulenberg CJW, Vijverberg HPM. 2000. Empirical relations predicting human and rat tissue: Air partition coefficients of volatile organic compounds. Toxicol Appl Pharmacol 165(3):206–216.10873711
Milman HA, Mitoma C, Tyson C, . 1984. Comparative pharmacokinetics/metabolism, carcinogenicity and mutagenicity of chlorinated ethanes and ethylenes (meeting abstract). Arbete och Halsa 29:19.
Milman HA, Story DL, Riccio ES, . 1988. Rat liver foci and in vitro assays to detect initiating and promoting effects of chlorinated ethanes and ethylenes. Ann NY Acad Sci 534:521–530.3389679
Minot GR, Smith LW. 1921. The blood in tetrachloroethane poisoning. Arch Intern Med 28:687–702.
Mirsalis JC, Tyson CK, Steinmetz KL, . 1989. Measurement of unscheduled DNA synthesis and s-phase synthesis in rodent hepatocytes following in vivo treatment: Testing of 24 compounds. Environ Mol Mutagen 14:155–164.2792091
Mitoma C, Steeger T, Jackson SE, . 1985. Metabolic disposition study of chlorinated hydrocarbons in rat and mice. Drug Chem Toxicol 3:183–194.
Mitoma C, Tyson CA, Riccio ES. 1984. Investigations of the species sensitivity and mechanism of carcinogenicity of halogenated hydrocarbons, final report. SRI International. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0509408.
Miyagawa M, Takasawa H, Sugiyama A, . 1995. The in vivo-in vitro replicative DNA synthesis (RDS) test with hepatocytes prepared from male B6C3F1 mice as an early prediction assay for putative nongenotoxic (Ames-negative) mouse hepatocarcinogens. Mutat Res 343:157–183.7791810
Mohamed MF, Kang D, Aneja VP. 2002. Volatile organic compounds in some urban locations in United States. Chemosphere 47:863–882.12079081
Montgomery JH, Welkom LM. 1990. Groundwater chemicals desk reference. Chelsea, MI: Lewis Publishers, 491–495.
Morgan A, Black A, Belcher DR. 1970. The excretion in breath of some aliphatic halogenated hydrocarbons following administration by inhalation. Ann Occup Hyg 13:219.5509094
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5:485–527.
Mosesman NH, Sidisky LM, Corman SD. 1987. Factors influencing capillary analyses of volatile pollutants. J Chromatogr Sci 25:351–355.
Mouradian RF, Levine SP, Ke HQ, . 1991. Measurement of volatile organics at part per billion concentrations using a cold trap inlet and high speed gas chromatography. J Air Waste Manage Assoc 41:1067–1072.
Mudder TI, Musterman JL. 1982. Development of empirical structure biodegradability relationships and biodegradability testing protocol for volatile and slightly soluble priority pollutants. Presented before the Division of Environmental Chemistry of the American Chemical Society, Kansas City, MO, September 1982, 52–53.
*Nakajima T, Sato A. 1979. Enhanced activity of liver drug metabolizing enzymes for aromatic and chlorinated hydrocarbons following food deprivation. Toxicol Appl Pharmacol 50:549–556.516066
NARA. 2006. Code of federal regulations. Washington, DC: National Archives and Records Administration. http://www.access.gpo.gov/nara/cfr/cfr-table-search.html. March 20, 2006.
NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Science, National Research Council. Washington, DC: National Academy Press, 15–35.
Navrotskiy VK, Kashin LM, Kulinskoya IL. 1971. [Comparative assessment of the toxicity of a number of industrial poisons when inhaled in low concentrations for prolonged periods.] Trudy S’ezda Gig Ukran 8:224–226. (Russian)
Naylor Dana Institute. 1983. DNA repair tests of 11 chlorinated hydrocarbon analogs final report EPA contract. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0509403.
NCI. 1976. Carcinogenesis bioassay of trichloroethylene (CAS No. 79-01-6). Bethesda, MD: National Cancer Institute, Division of Cancer Cause and Prevention, Carcinogenesis Program, Carcinogen Bioassay and Program Resources Branch. NCI-CG-TR-2, DHEW Publ. No. (NIH) 76-802.
NCI. 1977. Bioassay of tetrachloroethylene for possible carcinogenicity. Bethesda, MD: National Cancer Institute. U.S. Department of Health, Education, and Welfare, Public Health Service, National Institutes of Health, DHEW Publ (NIH) 77-813.
NCI. 1978. Bioassay of 1,1,2,2-tetrachloroethane for possible carcinogenicity. National Cancer Institute. PB2774537, 90.
Nebert DW, Adesnik M, Coon MJ, . 1987. The P450 gene superfamily: Recommended nomenclature. DNA 6(1):1–11.3829886
NEMI. 1997a. Method 6200B: Volatile organic compounds in water by purge and trap capillary-column GC/MS method. National Environmental Methods Index. U.S. Environmental Protection Agency. U.S. Geological Survey. http://www.nemi.gov. April 20, 2006.
NEMI. 1997b. Method 6200C: Volatile organic compounds in water by purge and trap capillary-column GC method. National Environmental Methods Index. U.S. Environmental Protection Agency. U.S. Geological Survey. http://www.nemi.gov. April 20, 2006.
NEMI. 2001. Method D5790: Standard test method for measurement of purgeable organic compounds in water by capillary column gas chromatography/mass spectrometry. National Environmental Methods Index. U.S. Environmental Protection Agency. U.S. Geological Survey. http://www.nemi.gov. April 20, 2006.
Nestmann ER, Lee EGH. 1983. Mutagenicity of constituents of pulp and paper mill effluent in growing cells of Saccharomyces cerevisiae. Mutat Res 119:273–280.6338377
Nestmann ER, Lee EG-H, Matula TI, . 1980. Mutagenicity of constituents identified in pulp and paper mill effluents using the Salmonella mammalian-microsome assay. Mutat Res 79:203–212.7012602
NIOSH. 1978. Toxicity data for establishing “immediately dangerous to life or health” (IDLH) values. Cincinnati, OH: National Institute for Occupational Safety and Health. PB87163531.
NIOSH. 1980. Tier II mutagenic screening of 13 NIOSH priority compounds, individual compound report, 1,1,2,2-tetrachloroethane, Report No 26. Cincinnati, OH: National Institute for Occupational Safety and Health. PB83149369.
NIOSH. 1992. Recommendations for occupational safety and health; Compendium of policy documents and statements. Cincinnati, OH: U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health, 124, 161–170.
NIOSH. 1994. Method 1019. Manual of analytical methods 1,1,2,2,-tetrachloroethane. 4th ed. Cincinnati, OH: U.S. Department of Health, Education, and Welfare, National Institute for Occupational Safety and Health.
NIOSH. 2005. 1,1,2,2 Tetrachloroethane. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/. March 08, 2006.
NIOSH. 2006. 1,1,2,2-Tetrachloroethane. National occupational exposure survey 1981-83. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control. National Institute for Occupational Safety and Health, July 1, 1990.
Norman JE, Jr, Robinette CD, Fraumeni JF, Jr. 1981. The mortality experience of Army World War II chemical processing companies. J Occup Med 23:818–822.
NRC. 1993. Pesticides in the diets of infants and children. Washington, DC: National Academy Press. National Research Council.
NTP. 1986. National Toxicology Program--technical report series no. 311. Toxicology and carcinogenesis studies of tetrachloroethylene (perchloroethylene) (CAS No. 127- 18-4) in F344/N rats and B6C3Fl mice (inhalation studies). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health, NIH publication no. 86-2567.
NTP. 1990. National Toxicology Program--technical report series no. 243. Carcinogenesis studies of trichloroethylene (without epichlorohydrinin) (CAS No. 79-01-6) in Fischer-344/N rats and B6C3F1 mice (gavage studies). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. NIH publication no. 90-1799.
NTP. 1991a. Report: Range finding studies: Developmental toxicity 1,1,2,2-tetrachloroethane when administered via feed in CD Sprague-Dawley rats. Prepared by Environmental Health Research and Testing, Inc., Contract NO1-ES-95249. National Toxicology Program. NTP-91-RF/DT-017. TRP 91029.
NTP. 1991b. Report: Range finding studies: Developmental toxicity 1,1,2,2-tetrachloroethane (repeat) then administered via feed in Swiss CD-1 mice. Prepared by Environmental Health Research and Testing, Inc., Contract NO1-ES-95249. National Toxicology Program. NTP-91-RF/DT-020. TRP 91069.
NTP. 1993a. 14-Day pilot gavage toxicity study of 1,1,2,2-tetrachloroethane in male F344/N rats. Prepared by TSI Mason Laboratories, Contract NO1-ES-15326. National Toxicology Program. MLI-NTP-13-93-13.
NTP. 1993b. 14-Day pilot gavage toxicity study of 1,1,2,2-tetrachloroethane in male F344/N rats. Prepared by TSI Mason Laboratories, Contract NO1-ES-15326. National Toxicology Program. MLI-NTP-1-93-1.
NTP. 1993c. 14-Day pilot dosed feed toxicity study of microencapsulated 1,1,2,2-tetrachloroethane in B6C3F1 mice. Prepared by TSI Mason Laboratories, Contract NO1-ES-15326. National Toxicology Program. MLI-NTP-9-93-9.
NTP. 1993d. 14-Day pilot gavage toxicity study of 1,1,2,2-tetrachloroethane in B6C3F1 mice. Prepared by TSI Mason Laboratories, Contract NO1-ES-15326. National Toxicology Program. MLI-NTP-10-93-10.
NTP. 1996. NTP technical report on renal toxicity studies of selected halogenated ethanes administered by gavage to F344/N rats. Research Triangle Park, NC: United States Department of Health and Human Services, Public Health Service National Institutes of Health, National Toxicology Program, 1–52.
NTP. 2004a. NTP technical report on the toxicity studies of 1,1,2,2-tetrachloroethane (CAS No. 79-34-5) administered in microcapsules in feed to F344/N rats and B6C3F1 mice. National Toxicology Program. Tox-49. http://ntp.niehs.nih.gov/ntp/htdocs/ST_rpts/tox049.pdf. October 04, 2004.
NTP. 2004b. Report on carcinogens. 11th ed. Research Triangle Park, NC: National Toxicology Program, Department of Health and Human Services. http://ntp-server.niehs.nih.gov/ntp/roc/toc11.html. January 11, 2008.
Ohio River Valley Sanitation Commission. 1980. Assessment of water quality conditions, Ohio River mainstream, 1978-1979. Cincinnati, OH: Ohio River Valley Water Sanitation Commission.
Omiecinski CJ, Remmel RP, Hosagrahara VP. 1999. Concise review of the cytochrome P450s and their roles in toxicology. Toxicol Sci 48:151–156.10353305
O’Neil MJ, Smith A, Heckelman PE, ., eds. 2001. Merck index: an encyclopedia of chemicals, drugs, and biologicals. 13th ed. Rahway NJ: Merck & Co., Inc., 1640.
Ono Y, Kobayashi U, Somiya I, . 1996. Evaluation of DNA damage by active oxygen induced by organochlorine compounds and nitroarenes. Mizu Kankyo Gakkaishi 19:87–877.
OSHA. 1991. Air contaminants. Occupational standards permissible exposure limits. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000.
OSHA. 2006a. Air contaminants. Occupational safety and health standards for shipyard employment. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. http://www.osha.gov/comp-links.html. March 08, 2006.
OSHA. 2006b. Gases, vapors, fumes, dusts, and mists. Safety and health regulations for construction. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55, Appendix A. http://www.osha.gov/comp-links.html. March 08, 2006.
OSHA. 2006c. Limits for air contaminants. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. http://www.osha.gov/comp-links.html. March 08, 2006.
*OTA. 1990. Neurotoxicity: Identifying and controlling poisons of the nervous system. Washington, DC: Office of Technology Assessment, U.S. Congress. OTA-BA-438, April 1990.
Otson R. 1987. Purgeable organics in Great Lakes raw and treated water. Intern J Environ Anal Chem 31:41–53.
Otson R, Williams DT. 1982. Headspace chromatographic determination of water pollutants. Anal Chem 54:942–946.
Otson R, Fellin P, Tran Q. 1994. VOCs in representative Canadian residences. Atmos Environ 28(22):3563–3569.
Otson R, Williams DT, Bothwell PD. 1982. Volatile organic compounds in water at thirty Canadian potable water treatment facilities. J Assoc Off Anal Chem 65:1370–1374.
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Page GW. 1981. Comparison of groundwater and surface water for patterns and levels of contamination by toxic substances. Environ Sci Technol 15(12):1475–1481.
Pankow JR, Rosen ME. 1988. Determination of volatile compounds in water by purging directly to a capillary column with whole column cryotrapping. Environ Sci Technol 22:398–405.
Pankow JF, Isabelle LM, Asher WE. 1984. Trace organic compounds in rain. I. Sampler design and analysis by adsorption/thermal desorption (ATD). Environ Sci Technol 18:310–318.22280076
Pantelitsch M. 1933. [Experiments concerning the effect of chlorinated methane and ethane on mice--The relative sensitivity of mice and cats to poisons.] Inaugural Dissertation, Hygienischen Institute der Universitat Wurzburg, 1–13. (German)
Paolini M, Sapigni E, Mesirca R, . 1992. On the hepatotoxicity of 1,1,2,2-tetrachloroethane. Toxicology 73:101–115.1317068
Parmenter DC. 1921. Tetrachloroethane poisoning and its prevention. J Ind Hyg 2:456–465.
Parraga M, West JM. 1998. Hydrocarbons. In: Viccellio P, ed. Emergency toxicology. Philadelphia, PA: Lippincott-Raven Publishers, 299–313.
Pellizzari ED. 1982. Analysis for organic vapor emissions near industrial and chemical waste disposal sites. Environ Sci Technol 16:781–785.22299786
Pellizzari ED, Hartwell TD, Harris BSH, . 1982. Purgeable organic compounds in mother’s milk. Bull Environ Contam Toxicol 28:322–328.7082873
Pereira MA. 1996. Carcinogenic activity of dichloroacetic acid and trichloroacetic acid in the liver of female B6C3F1 mice. Fundam Appl Toxicol 31:192–199.8789785
Pereira MA, Phelps JB. 1996. Promotion by dichloroacetic acid and trichloroacetic acid of N-methyl-N-nitrosourea-initiated cancer in the liver of female B6C3F1 mice. Cancer Lett 102:133–141.8603361
*Plaa GL, Larson RE. 1965. Relative nephrotoxic properties of chlorinated methane, ethane, and ethylene derivatives in mice. Toxicol Appl Pharmacol 7:37–44.14256601
*Plaa GL, Evans EA, Hine CH. 1958. Relative hepatotoxicity of seven halogenated hydrocarbons. J Pharmacol Exp Ther 123:224–229.13564399
Plumb RH. 1991. The occurrence of Appendix IX organic constituents in disposal site ground water. Ground Water Monit Rev 11(2):157–164.
Pratt GC, Palmer K, Wu CY, . 2000. An assessment of air toxics in Minnesota. Environ Health Perspect 108(9):815–825.11017885
Quack B, Suess E. 1999. Volatile halogenated hydrocarbons over the western Pacific between 43° and 4°N. J Geophys Res 104(D1):1663–1678.
Ramsey JC, Andersen ME. 1984. A physiologically based description of the inhalation pharmacokinetics of styrene in rats and humans. Toxicol Appl Pharmacol 73:159–175.6710512
Redmond MS, Crocker PA, McKenna KM, . 1996. Sediment toxicity testing with the amphipod Ampelisca abdita in Calcasieu Estuary, Louisiana. Arch Environ Contam Toxicol 30:53–61.
Richmond RE, Carter JH, Carter HW, . 1995. Immunohistochemical analysis of dichloroacetic acid (DCA)-induced hepatocarcinogenesis in male Fischer (F344) rats. Cancer Lett 92:67–76.7538896
Roldan-Arjona T, Garcia-Pedrajas MD, Luque-Romero FL, . 1991. An association between mutagenicity of the Ara test of Salmonella typhimurium and carcinogenicity in rodents for 16 halogenated aliphatic hydrocarbons. Mutagenesis 6:199–205.1881351
Rosenkranz HS. 1977. Mutagenicity of halogenated alkanes and their derivatives. Environ Health Perspect 21:79–84.348460
Rossberg M, Aktiengesellschaft H, Lendle W, . 2005. Chlorinated hydrocarbons. In: Ullman’s encyclopedia of industrial chemistry. Weinheim, Germany: Wiley-VCH Verlag, 1–184.
RTECS. 2006. 1,1,2,2-Tetrachloroethane. Registry of Toxic Effects on Chemical Substances. National Institute of Occupational Safety and Health. MDL Information Systems, Inc. April 1, 2006.
Ryan DA, Argentine SM, Rice GW. 1990. Helium discharge detector for quantitation of volatile organohalogen compounds. Anal Chem 62:853–857.2349999
Sabel GV, Clark TP. 1984. Volatile organic compounds as indicators of municipal solid waste leachate contamination. Waste Manag Res 2:119–130.
Sack TM, Steele DH, Hammerstrom K, . 1992. A survey of household products for volatile organic compounds. Atmos Environ 26A:1063–1070.
Sato A, Nakajima T, Koyama Y. 1980. Effects of chronic ethanol consumption on hepatic metabolism of aromatic and chlorinated hydrocarbons in rats. Br J Ind Med 37:382–386.7192567
*Schmidt R. 1976. [The embryotoxic and teratogenic effect of tetrachloroethane experimental studies.] Biol Rundsch 14:220–223. (German)
Schmidt P, Binnevies S, Gohlke R, . 1972. [Subacute action of low concentration of chlorinated ethanes on rats with and without additional ethanol treatment. I. Biochemical and toxicometrical aspects, especially results in subacute and chronic toxicity studies with 1,1,2,2-tetrachloroethane.] Int Arch Arbeitsmed 30:283–298. (German)4346601
Schmidt P, Burck D, Buerger A, . 1980b. [On the hepatotoxicity of benzene, 1,1,2,2-tetrachloroethane and carbon tetrachloride.] Gesamte Hyg Ihre Grenzgeb 26:167–172. (German)
Schmidt P, Gohlke R, Just A, . 1980a. [Combined action of hepatotoxic substances and increased environmental temperature on the liver of rats.] J Hyg Epidemiol Microbiol Immunol (Prague) 24:271–277. (German)
*Schmidt P, Ulano IP, Avilova GG, . 1975. [Comparison of the processes of adaptation of the organism to monotonic and intermittent exposure to 1,1,2,2-tetrachloroethane.] Gig Tr Prof Zabol 2:30–34. (Russian)
Setchell BP, Waites GMH. 1975. The blood-testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society, 143–172.
Shackelford WM, Cline DM, Faas L, . 1983. An evaluation of automated spectrum matching for survey identification of wastewater components by gas chromatography-mass spectrometry. Anal Chim Acta 146:15–27.
Sherman JB. 1953. Eight cases of acute tetrachloroethane poisoning. J Trop Med Hyg 56:139–140.13062363
Shilling RD. 1985. Air stripping provides fast solution for polluted well water. Pollution Engineering 17:25–27.
Shmuter LM. 1977. [The effect of chronic exposure to low concentration of ethane series chlorinated hydrocarbons on specific and nonspecific immunological reactivity in animal experiments.] Gig Tr Prof Zabol 8:38–43. (Russian)
Sieber WK, Sundin DS, Frazier TM, . 1991. Development use and availability of a job exposure matrix based on national occupational hazard survey data. Am J Ind Med 20:163–174.1951366
Singh HB, Salas LJ, Smith AJ, . 1981. Measurements of some potentially hazardous organic chemicals in urban environments. Atmos Environ 15:601–612.
Singh HB, Salas LJ, Stiles RE. 1982. Distribution of selected gaseous mutagens and suspected carcinogens in ambient air. Environ Sci Technol 16:872–880.22236265
Smyth HF Jr, Carpenter CP, Weil CS, . 1969. Range-finding toxicity data-List VII. Am Ind Hyg Assoc J 30:470–476.5823428
Soucek P, Gut I. 1992. Cytochromes P-450 in rats: Structures, functions, properties and relevant human forms. Xenobiotica 22:83–103.1615711
Spence JR, Hanst PL. 1978. Oxidation of chlorinated ethanes. JAPCA 28:250–253.
Spicer CW, Buxton BE, Holdren MW, . 1996. Variability of hazardous air pollutants in an urban area. Atmos Environ 30(20):3443–3456.
SRI. 1988. 1,1,2,2-Tetrachloroethane. Guide to chemical producers. Stanford Research Institute. Menlo Park, CA: SRI International, 123, 124, 1017.
SRI. 1992. 1,1,2,2-Tetrachloroethane. 1992 Directory of chemical producers. Stanford Research Institute. Menlo Park, CA: SRI International, 412, 1016.
SRI. 1993. 1,1,2,2-Tetrachloroethane. 1993 Directory of chemical producers. Stanford Research Institute. Menlo Park, CA: SRI International, 411.
Story DL, Meierhenry EF, Tyson CA, . 1986. Difference in rat liver enzyme-altered foci produced by chlorinated aliphatics and phenobarbital. Toxicol Ind Health 2:351–362.3296316
Streete PJ, Ruprah M, Ramsey JD, . 1992. Detection and identification of volatile substances by headspace capillary gas chromatography to aid the diagnosis of acute poisoning. Analyst 117:1111–1127.1524229
Strobel K, Grummt T. 1987. Aliphatic and aromatic halocarbons as potential mutagens in drinking water. III. Halogenated ethanes and ethenes. Toxicol Environ Chem 15:101–128.
Swann RL, Laskowski DA, McCall PJ, . 1983. A rapid method for the estimation of the environmental parameters octanol, water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Res Rev 85:17–28.
Tabak HH, Quave SA, Mashni CI, . 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Contr Fed 53:1503–1518.
*Takeuchi Y. 1966. Experimental studies on the toxicity of 1,1,1,2-tetrachloroethane compared with 1,1,2,2-tetrachloroethane and 1,1,1-trichloroethane. Jpn J Ind Health 8:371–375.
Tam BN, Neumann CA. 2004. A human health assessment of hazardous air pollutants in Portland, OR. J Environ Manage 73(2):131–145.15380318
*Theiss JC, Stoner GD, Shimkin MB, . 1977. Test for carcinogenicity of organic contaminants of United States drinking waters by pulmonary tumor response in strain A mice. Cancer Res 37/8:2717–2720.
Thomas RG. 1990. Volatilization from water. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods. New York, NY: McGraw-Hill Book Co., 15-9 to 15-30.
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ: Princeton Scientific Publishing, 365–394.
Tomasi A, Albano E, Bini A, . 1984. Free radical intermediates under hypoxic conditions in the metabolism of halogenated carcinogens. Toxicol Pathol 12:240–246.6393297
TOMES. 1993. Toxicology, Occupational Medicine and Environment Series, electronic data base. Tetrachloroethane. Micromedex, Inc. Vol. 78. http://www.micromedex.com/products/tomes/. August 1, 2006.
Tomkins BA, Caton JE, Edwards MD, . 1989. Determination of regulatory organic compounds in radioactive waste samples. Volatile organics in aqueous liquids. Anal Chem 61:2751–2756.
Tomokuni K. 1969. Studies on hepatotoxicity induced by chlorinated hydrocarbons. Lipid and ATP metabolisms in the liver of mice exposed to 1,1,2,2-tetrachloroethane. Acta Med Okayama 23:273–282.
Tomokuni K. 1970. Hepatotoxicity induced by chlorinated hydrocarbons. II. Lipid metabolism and absorption spectrum of microsomal lipids in the mice exposed to 1,1,2,2-tetrachloroethane. Acta Med Okayama 24:315–322.
Tosato ML, Chiorboli C, Eriksson L, . 1991. Multivariate modeling of the rate constant of the gas-phase reaction of haloalkanes with the hydroxyl radical. Sci Total Environ 109/110:307–325.
Travis CC, Holton GA, Etnier EL, . 1986. Assessment of inhalation and ingestion population exposures from incinerated hazardous wastes. Environ Int 12:533–540.
TRI05. 2007. TRI exporer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. December 21, 2007.
Truffert L, Girard-Wallon C, Emmerich E, . 1977. [Early experimental demonstration of the hepatotoxicity of some chlorinated solvents by the study of the synthesis of hepatic DNA.] Arch Mal Prof Med Trav Secur Soc 38:261–263. (French)
Tsuruta H. 1975. Comparative study in the in vivo percutaneous absorptions of chlorinated solvents in mice. Ind Health 13:227–236
Tu AS, Murray TA, Hatch KM, . 1985. In vitro transformation of BALB/c-3T3 cells by chlorinated ethanes and ethylenes. Cancer Lett 28:85–92.4027960
Union Carbide Corporation. 1947. Repeated exposure of rats and dogs to vapors of eight chlorinated hydrocarbons. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0515559.
U.S. Department of Commerce. 2006. 2903191000--Hexachloroethane and tetrachloroethane. U.S. Department of Commerce. Office of Trade and Industry Information (OTII), International Trade Administration. http://www.ita.doc.gov/td/industry/otea/Trade-Detail/. March 30, 2006.
USGS. 1983. Total recoverable purgeable organic compounds in water by purge and trap gas chromatography with a mass spectrometer. In: Methods for the determination of organic substances in water and fluvial sediments, techniques of water-resources investigations of the United States Geological Survey. Denver, CO: U.S. Geological Survey. http://web1.er.usgs.gov/nemi/method_summary.jsp?param_method_id=4772. June 5, 2006.
USGS. 1998. Methods of analysis by the U.S. Geological Survey National Water Quality Laboratory: Determination of 86 volatile organic compounds in water by gas chromatography/mass spectrometry, including detections less than reporting limits. Denver, CO: U.S. Geological Survey. Open File Report 97-829.
USGS. 2001. Ground-water quality in the Cook Inlet Basin, Alaska, 1999. Anchorage, AK: U.S. Geological Survey, U.S. Department of the Interior. WRI Report No. 01-4208.
USGS. 2002. Quality of shallow ground water in areas of recent residential and commercial development, Wichita, Kansas, 2000. U S Geological Survey- U S Department of the Interior. Water Resources Investigation Report 02-4228. http://ks.water.usgs.gov/Kansas/pubs/reports/wrir.02-4228.pdf. December 26, 2007.
USITC. 1994. Harmonized tariff schedule of the United States 1994. Washington, DC: U.S. International Trade Commission Publication 2690.
*Vainio H, Parkki MG, Marniemi J. 1976. Effects of aliphatic chlorohydrocarbons on drug-metabolizing enzymes in rat liver in vivo. Xenobiotica 6(10):599–604.824867
Valsaraj KT, Kommalapati RR, Robertson ED, . 1999. Partition constants and adsorption/desorption hysteresis for volatile organic compounds on soil from a Louisiana superfund site. Environ Monit Assess 58:225–241.
*Van Dyke RA, Wineman CG. 1971. Enzymatic dechlorination of chloroethanes and propanes in vitro. Biochem Pharmacol 20:463–470.4402457
Verschueren K. 2001. Handbook of environmental data on organic chemicals. 4th ed. New York, NY: John Wiley & Sons, Inc., 1946–1947.
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
Vogel EW, Nivard MJM. 1993. Performance of 181 chemicals in a Drosophila assay predominantly monitoring interchromosomal mitotic recombination. Mutagenesis 8:57–81.8450769
Ward JM. 1955. Accidental poisoning with tetrachloroethane. Br Med J 1:1136.14363814
Warner JR, Hughes TJ, Claxton LD. 1988. Evaluation of a protocol for preparing soil and sediment samples for AMES mutagenicity testing. Environ Mol Mutagen 11:111.
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
Westrick JJ, Mello JW, Thomas RF. 1984. The groundwater supply survey. J Am Water Works Assoc 76:52–59.
WHO. 1998. 1,1,2,2-Tetrachloroethane. Concise international chemical assessment document no. 3. International programme on chemical safety. Geneva, Switzerland: World Health Organization. http://www.inchem.org/documents/cicads/cicads/cicad03.htm. April 07, 2006.
WHO. 2000. Air quality guidelines. 2nd ed. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/Document/AIQ/AirQualRepMtg.pdf. March 08, 2006.
WHO. 2004. Guidelines for drinking-water quality. 3rd ed. Geneva, Switzerland: World Health Organization. http://www.who.int/water_sanitation_health/dwq/gdwq3/en/. March 08, 2006.
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York: Academic Press, 1–247.
Willcox WH, Spilsbury BH, Legge TM. 1915. An outbreak of toxic jaundice of a new type amongst aeroplane workers-Its clinical and toxicological aspect. Trans Med Soc London 38:129–156.
Wilson SC, Burnette V, Waterhouse KS, . 1994. Volatile organic compounds in digested United Kingdom sewage sludges. Environ Sci Technol 28(2):259–266.22176171
*Wolff DL, Siegmund R. 1978. [The circadian-dependent effect of trichloroethylene on spontaneous locomotor activity and of tetrachloroethane on mortality in mice.] Biol Zentralbl 97(3):345–351. (German)
Wolff L. 1978. The effect of 1,1,2,2-tetrachloroethane on passive avoidance learning and spontaneous locomotor activity. Activ Nerv Sup (Praha) 20:14–16.636751
Woodruff RC, Mason JM, Valencia R, . 1985. Chemical mutagenesis testing in drosophila. 5. Results of 53 coded compounds tested for the National Toxicology Program. Environ Mutagen 7:677–702.3930237
Yasuda SK, Loughran ED. 1977. Air sampling methods for S-tetrachloroethane and other related chlorinated hydrocarbons. J Chromatogr 137:283–292.881453
Yieru H, Qing-Yu O, Weile Y. 1990a. The effect of compound structure on the elemental responses in gas chromatography - microwave induced plasma atomic emission spectrometry. J Chromatogr Sci 28:584–588.
Yieru H, Qing-Yu O, Weile Y. 1990b. Characteristics of flame ionization detection for the quantitative analysis of complex organic mixtures. Anal Chem 62:2063–2064.
Yllner S. 1971. Metabolism of 1,1,2,2-tetrachloroethane-14C in the mouse. Acta Pharmacol Toxicol 29:499–512.
Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372