# 8 REGULATIONS AND ADVISORIES

The international and national regulations and guidelines regarding 1,1,2,2-tetrachloroethane in air, water, and other media are summarized in Table 8-1.

ATSDR has derived an intermediate-duration oral MRL of 0.5 mg/kg/day for 1,1,2,2-tetrachloroethane based on a liver effect (minimal hepatocyte necrosis) in female rats administered the chemical in the diet for 14 weeks (NTP 2004a). The MRL was derived using benchmark dose modeling of the critical end point. The BMD corresponding to a BMR of 10% extra risk is 82.89 mg/kg/day; the corresponding BMDL_10_ is 53.88 mg/kg/day. An uncertainty factor of 100 (10 for interspecies extrapolation and 10 for human variability) was applied to the BMDL_10_ to calculate the MRL.

An EPA oral reference dose (RfD) and inhalation reference concentration (RfC) for 1,1,2,2-tetrachloroethane have not been derived.

The IARC classification for 1,1,2,2-tetrachloroethane is Group 3, not classifiable with regard to its carcinogenicity to humans (IARC 2004). The EPA cancer classification for 1,1,2,2-tetrachloroethane is Group C, possible human carcinogen (IRIS 2006). The National Toxicology Program has not classified 1,1,2,2-tetrachloroethane for human carcinogenicity (NTP 2004b). The American Conference of Governmental Industrial Hygienists (ACGIH) has classified 1,1,2,2-tetrachloroethane as an A3 carcinogen (confirmed animal carcinogen with unknown relevance to humans) (ACGIH 2005).

OSHA requires employers of workers who are occupationally exposed to 1,1,2,2-tetrachloroethane to institute engineering controls and work practices to reduce and maintain employee exposure at or below permissible exposure limits (PEL) (OSHA 2006c). The employer must use engineering and work practice controls to reduce exposure to or below an 8-hour time-weighted average (TWA) of 5 ppm (OSHA 2006c). Respirators must be provided and used during the time period necessary to install or implement feasible engineering and work practice controls (OSHA 2006c). ACGIH (2005) and NIOSH (2005) recommend a TWA exposure limit of 1 ppm for occupational exposure.

1,1,2,2-Tetrachloroethane is regulated by the Clean Water Effluent Guidelines as stated in Title 40, Section 400–475, of the Code of Federal Regulations. For each point source category, 1,1,2,2-tetrachloroethane may be regulated as one of a group of chemicals controlled as Total Toxic Organics, or may have a Zero Discharge Limitation. The point source categories for which 1,1,2,2-tetrachloroethane is controlled as a Total Toxic Organic include electroplating, metal finishing, and coil coating; see electronic Code of Federal Regulations for a complete listing (NARA 2006).

EPA regulates 1,1,2,2-tetrachloroethane under the Clean Air Act (CAA) and has designated it as a hazardous air pollutant (HAP) (EPA 2006a). 1,1,2,2-Tetrachloroethane is on the list of chemicals appearing in “The Emergency Planning and Community Right-to-Know Act of 1986” (EPCRA) (EPA 2006c) and has been assigned a reportable quantity (RQ) limit of 100 pounds (EPA 2006b). The RQ represents the amount of a designated hazardous substance which, when released to the environment, must be reported to the appropriate authority.

Table 8-1 Regulations and Guidelines Applicable to 1,1,2,2-Tetrachloroethane

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | Group 3^a^ | IARC 2004
WHO | Air quality guidelines | No data | WHO 2000
WHO | Drinking water quality guidelines | No data | WHO 2004
[underlined: NATIONAL]
Regulations andGuidelines:
a. Air
ACGIH | TLV (8-hour TWA) | 1 ppm^b^ | ACGIH 2005
EPA | AEGL | No data | EPA 2006h
EPA | Hazardous air pollutant | Yes | EPA 2006a; 42 USC 7412
NIOSH | REL (10-hour TWA) | 1 ppm^c,d^ | NIOSH 2005
NIOSH | IDLH | 100 ppm^c^ | NIOSH 2005
OSHA | PEL (8-hour TWA) for general industry | 100 ppm^e^ | OSHA 2006c; 29 CFR 1910.1000
OSHA | PEL (8-hour TWA) for construction industry | 5 ppm^e^ | OSHA 2006b; 29 CFR 1926.55, Appendix A
OSHA | PEL (8-hour TWA) for shipyard industry | 5 ppm^e^ | OSHA 2006a; 29 CFR 1915.1000
b. Water
DOT | Marine pollutant | Yes | DOT 2005; 9 CFR 172.101, Appendix B
EPA | Drinking water standards and health advisories | | EPA 2006i
EPA | 1-day health advisory for a 10-kg child | 0.04 mg/L
EPA | 10-day health advisory for a 10-kg child | 0.04 mg/L
EPA | DWEL | 0.002 mg/L
EPA | Lifetime | 3–10^−4^ mg/L
EPA | 10^−4^ Cancer risk | 0.02 mg/L
EPA | National primary drinking water standards | No data | EPA 2003
EPA | National recommended water quality criteria | | EPA 2006j
EPA | Human health for consumption of water + organism | 0.17 μg/L
EPA | Human health for consumption of organism only | 4.0 μg/L
EPA | Toxics criteria for those states not complying with Clean Water Act Section 303(c)(2)(B) for human health (10^−6^ risk for carcinogens) for consumption of: | | EPA 2006g 40 CFR 131.36
EPA | Water + organism | 0.17 μg/L
EPA | Organism only | 11 μg/L
c. Food
FDA | Bottled drinking water | No data | FDA 2005a 21 CFR 165.110
d. Other
ACGIH | Carcinogenicity classification | A3^f^ | ACGIH 2005
EPA | Carcinogenicity classification | Group C^g^ | IRIS 2006
EPA | Oral slope factor | 2×10^−1^ per mg/kg/day
EPA | Inhalation unit risk | 5.8×10^−5^ per ng/m^3^
EPA | RfC | No data
EPA | RfD | No data
EPA | Identification and listing of hazardous waste; hazardous waste number | U209 | EPA 2006k; 40 CFR 261, Appendix VIII
EPA | Superfund, emergency planning, and community right-to-know
EPA | Designated CERCLA hazardous substance | Yes | EPA 2006b 40 CFR 302.4
EPA | Reportable quantity | 100 pounds
EPA | Effective date of toxic chemical release reporting | 01/01/87 | EPA 2006c 40 CFR 372.65
NTP | Carcinogenicity classification | No data | NTP 2004b

a Group 3: not classifiable as to carcinogenicity to humans

b Skin notation: refers to the potential significant contribution to the overall exposure by the cutaneous route, including mucous membranes and the eyes, either by contact with vapors, liquids, or solids.

c Potential occupational carcinogen

d Skin designation: indicates the potential for dermal absorption; skin exposure should be prevented as necessary through the use of good work practices, gloves, coveralls, goggles, and other appropriate equipment.

e Skin designation

f A3: confirmed animal carcinogen with unknown relevance to humans

g Group C: possible human carcinogen

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = Acute Exposure Guideline Level; CERCLA = Comprehensive Environmetnal Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; DOT = Department of Transportation; DWEL = drinking water equivalent level; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; MCL = maximum contaminant level; MCLG = maximum contaminant level goal; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration;PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; STEL = short-term expsoure limit; TLV = threshold limit values; TWA = time-weighted average; USC = United States Code; WHO = World Health Organization