# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of 1,1,2,2-tetrachloroethane is located in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of 1,1,2,2-tetrachloroethane is located in Table 4-2.

Table 4-1 Chemical Identity of 1,1,2,2-Tetrachloroethane

Characteristics | Information | References
Chemical name | 1,1,2,2-Tetrachloroethane | Lide 2005
Synonyms | Tetrachloroethane; acetylene tetrachloride; dichloro-2,2-dichloroethane; s-tetrachloroethane | ChemID 2004
Trade names | Bonoform, Cellon, Westron, Acetosol | ChemID 2004; HSDB 2006
Chemical formula | C_2_H_2_Cl_4_ | O’Neil et al. 2001
Chemical structure | [image] | Lide 2005
Identification numbers:
CAS registry | 79-34-5 | ChemID 2004
NIOSH RTECS | KI8575000 | RTECS 2006
EPA hazardous waste | U209 | RTECS 2006
OHM/TADS | 8100014 | HSDB 1995
DOT/UN/NA/IMDG shipping | UN 1702; IMDG 6.1 | HSDB 2006
HSDB | 123 | HSDB 2006
NCI | NCI-C03554 | RTECS 2006

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG -Department of Transportation/United Nations/North America/ Intergovernmental Maritime Consultive Organization; EPA = Environmental Protection Agency; HSDB = Hazardous Substance Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data Base; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of 1,1,2,2-Tetrachloroethane

Property | Tetrachloroethane | References
Molecular weight | 167.85 | O’Neil et al. 2001
Color | Colorless | Lewis 2001
Physical state | Liquid | Lewis 2001
Melting point | −42.4 °C | O’Neil et al. 2001
Boiling point | 145.2 °C | Lide 2005
Density (20 °C) | 1.6 | Lewis 2001
Odor | Sweetish, suffocating, chloroform-like | O’Neil et al. 2001
Odor threshold
Water | 0.5 ppm | Amoore and Hautala 1983
Air | 1.5 ppm | Amoore and Hautala 1983
Solubility
Water at 25 °C | 2.83×10^3^ mg/L | Horvath et al. 1999
Organic solvents | Miscible with methanol, ethanol, benzene, ether, petroleum ether, carbon tetrachloride, chloroform, carbon disulfide, dimethylformamide, oils | O’Neil et al. 2001
Partition coefficients
Log octanol/water | 2.39 | Hansch et al. 1995
K_oc_ | 46, 83, 118, 173, 216, 240 | Borisover and Graber 1997; Chiou et al. 1979; Chu and Chan 2000; Valsaraj et al. 1999
Vapor pressure
25 °C | 4.62 mmHg | AIChE 1995
Henry’s law constant
atm/m^3^-molecule at 25 °C | 3.67×10^−4^ atm-m^3^/mol | Leighton and Calo 1981
Conversion factors
ppm (v/v) to mg/m^3^ in air (20 °C) | 1 ppm=6.98 mg/m^3^ | Verschueren 2001
mg/m^3^ to ppm (v/v) in air (20 °C) | 1 mg/m^3^=0.14 ppm | Verschueren 2001
Bioconcentration factor
BCF | 8, 2 | ASTER 1995; Barrows et al. 1980