# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Environmental Medicine, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Environmental Medicine, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-32, Atlanta, Georgia 30333.

## 1,1,2,2-Tetrachloroethane Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,1,2,2-Tetrachloroethane
CAS Number: | 79-34-5
Date: | June 2008
Profile Status: | Post-Public Third Draft
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key | 39
Species: | Rat

[underlined: Minimal Risk Level]: [0.5] mg/kg/day [ ] ppm

[underlined: Reference]: NTP. 2004a. NTP technical report on the toxicity studies of 1,1,2,2-tetrachloroethane (CAS No. 79-34-5) administered in microcapsules in feed to F433/N rats and B6C3F_1_ mice. Research Triangle Park, NC: National Toxicology Program. TR-49. NIH Publication No. 04-4414.

[underlined: Experimental design]: Groups of 10 male and 10 female F344/N rats were fed diets containing 0, 268, 589, 1,180, 2,300, or 4,600 ppm of microencapsulated 1,1,2,2-tetrachloroethane for 14 weeks. The reported average daily doses were 0, 20, 40, 80, 170, or 320 mg/kg/day; vehicle control (feed with empty microcapsules) and untreated control groups were used for both sexes. End points evaluated throughout the study included clinical signs, body weight, and feed consumption. Hematology (12 indices) and clinical chemistry (10 indices) were assessed on days 5 and 21 and at the end of the study; urinalyses were not performed. Necropsies were performed on all animals and selected organs (liver, heart, right kidney, lung, right testis, and thymus) were weighed. Comprehensive histological examinations were performed on untreated control, vehicle control, and high dose groups. Tissues examined in the lower dose groups were limited to bone with marrow, clitoral gland, liver, ovary, prostate gland, spleen, testis with epididymis and seminal vesicle, and uterus. Functional observational batteries (FOBs) (21 parameters) were performed on rats in both control groups and the 20, 40, and 80 mg/kg/day groups during weeks 4 and 13. Sperm evaluations and vaginal cytology evaluations were performed at 0, 40, 80, and 170 mg/kg/day. The sperm evaluations consisted of spermatid heads per testis and per gram testis, spermatid counts, and epididymal spermatozoal motility and concentration. The vaginal cytology evaluations consisted of percentage of time spent in the various estrus stages and estrous cycle length.

[underlined: Effects noted in study and corresponding doses]: All rats survived to the end of the study, but clinical signs of thinness and pallor were observed in all animals in the 170 and 320 mg/kg/day groups. Final body weights were statistically significantly lower than vehicle controls in males at 80, 170, and 320 mg/kg/day (7, 29, and 65% lower, respectively) and females at 40, 80, 170, and 320 mg/kg/day (3, 9, 29, and 56% lower, respectively); at 320 mg/kg/day, rats of both sexes lost weight. Feed consumption decreased with increasing dose level at 170 and 320 mg/kg/day and may have contributed to the reduced body weight gain and weight loss. Results of the FOBs showed no exposure-related findings of neurotoxicity. The hematology evaluations indicated that 1,1,2,2-tetrachloroethane affected the circulating erythroid mass in both sexes (Table A-1). There was evidence of a transient erythrocytosis, as shown by increases in hematocrit values, hemoglobin concentration, and erythrocyte counts on days 5 and 21 at ≥170 mg/kg/day. The erythrocytosis was not considered clinically significant and disappeared by week 14, at which time it was replaced by minimal to mild, dose-related anemia, as shown by decreases in hematocrit and hemoglobin at ≥40 mg/kg/day. For example, although males exposed to 40 mg/kg/day showed a statistically significant decrease in hemoglobin at week 14, the magnitude of the change was small (3.8%). The anemia was characterized as microcytic based on evidence suggesting that the circulating erythrocytes were smaller than expected; this included decreases in mean cell volumes, mean cell hemoglobin values, and mean cell hemoglobin concentration in both sexes at ≥80 mg/kg/day at various time points. At week 14, there were no changes in reticulocyte counts, suggesting that there was no erythropoietic response to the anemia; this was supported by bone marrow atrophy observed microscopically. As discussed by NTP (2004a), the erythrocytosis suggested a physiological response consistent with the hemoconcentration of dehydration, and compromised nutritional status due to the reduced weight gain and food consumption may have contributed to the development of the anemia.

Table A-1 Body Weight, Liver Weight, and Selected Serum Chemistry and Hematology Changes in Rats Exposed to 1,1,2,2-Tetrachloroethane in the Diet for 14 Weeks^a^

End point | Vehicle control | Dose (mg/kg/day)
End point | Vehicle control | 20 | 40 | 80 | 170 | 320
Males (10/group)
Body weight (g) | 366±5 | 354±9 | 353±6 | 341±6^b^ | 259±9^b^ | 127±5^b^
Liver weight
absolute (g) | 12.74±0.26 | 12.99±0.35 | 14.47±0.44 | 15.54±0.39 | 11.60±0.44^b^ | 6.57±0.18^b^
relative (%) | 34.79±0.42 | 36.72±0.44 | 41.03±0.85^b^ | 45.61±0.52^b^ | 44.68±0.45^b^ | 52.23±1.42^b^
Serum total protein (g/dL) | 7.2±0.1 | 7.3±0.1 | 7.3±0.1 | 7.3±0.1 | 6.7±0.1^b^ | 6.0±0.1^b^
Serum cholesterol (mg/dL) | 73±2 | 74±3 | 76±2 | 67±2 | 68±2 | 65±2^b^
ALT (IU/L) | 48±2 | 49±2 | 53±2 | 69±3^b^ | 115±8^b^ | 292±18^b^
ALP (IU/L) | 256±7 | 260±5 | 248±5 | 245±6 | 353±12^b^ | 432±24^b^
SDH (IU/L) | 23±1 | 27±1^b^ | 26±2 | 31±1^b^ | 47±2^b^ | 74±4^b^
Bile acids (μmol/L) | 29.2±2.9 | 27.5±2.7 | 27.2±2.7 | 35.9±3.9 | 92.0±16.6^b^ | 332.4±47.4^b^
Hematocrit (%) (automated) | 45.2±0.5 | 44.9±0.4 | 44.0±0.9 | 43.3±0.7 | 43.1±0.6^b^ | 39.0±1.1^b^
Hemoglobin (Hb) (g/dL) | 15.8±0.1 | 15.6±0.1 | 15.2±0.3^b^ | 14.9±0.1^b^ | 14.6±0.1^b^ | 13.6±0.3^b^
Mean cell volume (fL) | 50.7±0.1 | 51.8±0.3 | 52.3±0.2 | 51.3±0.2 | 49.4±0.2 | 44.4±0.4^b^
Mean cell Hb (pg) | 17.7±0.1 | 18.1±0.1 | 18.0±0.1 | 17.7±0.2 | 16.8±0.1^b^ | 15.5±0.2^b^
Platelets (10^3^/μL) | 728.4±12.3 | 707.0±5.8 | 727.0±25.2 | 716.3±9.7 | 692.8±12.6^b^ | 773.4±23.2^b^
Females (10/group)
Body weight (g) | 195±4 | 192±4 | 189±2 | 177±2^b^ | 139±4^b^ | 85±3^b^
Liver weight
absolute (g) | 6.84±0.17 | 7.03±0.12 | 7.14±0.16 | 7.80±0.08^b^ | 6.66±0.21 | 4.94±0.12^b^
relative (%) | 35.07±0.56 | 36.69±0.36 | 37.84±0.51^b^ | 44.20±0.27^b^ | 48.03±0.89^b^ | 58.40±1.42^b^
Serum total protein (g/dL) | 7.2±0.1 | 7.3±0.0 | 7.3±0.1 | 6.9±0.1 | 6.4±0.1^b^ | 5.6±0.1^b^
Serum cholesterol (mg/dL) | 104±4 | 105±3 | 98±1 | 81±2^b^ | 64±3^b^ | 55±3^b^
ALT (IU/L) | 46±2 | 42±1 | 41±2 | 49±2 | 112±7^b^ | 339±18^b^
ALP (IU/L) | 227±5 | 216±4 | 220±3 | 225±11 | 341±7^b^ | 468±22^b^
SDH (IU/L) | 27±1 | 27±1 | 28±2 | 25±1 | 45±3^b^ | 82±3^b^
Bile acids (μmol/L) | 37.0±7.1 | 46.6±6.5 | 39.1±5.6 | 36.3±3.9 | 39.3±7.9 | 321.5±50.6^b^
Hematocrit (%) (automated) | 42.8±0.4 | 43.2±0.4 | 42.1±0.4 | 40.1±0.5^b^ | 42.8±0.7 | 34.7±0.7^b^
Hb (g/dL) | 15.2±0.1 | 15.3±0.1 | 14.9±0.1 | 14.2±0.2^b^ | 14.5±0.2^b^ | 12.5±0.2^b^
Mean cell volume (fL) | 55.4±0.1 | 56.1±0.1 | 55.8±0.1 | 53.3±0.2^b^ | 49.0±0.2^b^ | 44.4±0.4^b^
Mean cell Hb (pg) | 19.7±0.1 | 19.8±0.1 | 19.7±0.1 | 18.9±0.1^b^ | 16.6±0.2^b^ | 16.0±0.2^b^
Platelets (10^3^/μL) | 742.1±20.4 | 725.9±12.7 | 733.9±8.8 | 727.4±14. | 2 639.4±9.9^b^ | 662.5±19.4^b^

a Mean±standard error.

b Significantly different (p ≤0.05) from control value by William’s test (body and liver weight data) or Dunn’s or Shirley’s test (clinical chemistry and hematology data).

ALP = alkaline phosphatase; ALT = alanine aminotransferase; SDH = sorbitol dehydrogenase

Source: NTP 2004a

Statistically significant increases in absolute and relative liver weights were observed in males and females exposed to ≥40 mg/kg/day (Table A-1). Significant alterations in absolute and/or relative weights were also observed in several other organs, but these changes likely reflected the decreased body weight gain associated with reduced food intake. Changes in serum clinical chemistry parameters indicative of liver damage were observed in both sexes, generally occurring at all time points (day 5, day 21, and week 14) and generally increasing in magnitude with increasing dose and time. At week 14 (Table A-1), these effects included statistically significant increases in ALT and SDH in males at ≥80 mg/kg/day and females at ≥170 mg/kg/day, increases in ALP in both sexes at ≥170 mg/kg/day, increases in bile acids in males at ≥170 mg/kg/day and females at 320 mg/kg/day, and decreases in serum cholesterol in females at ≥80 mg/kg/day and males at 320 mg/kg/day. There were no exposure-related changes in serum 5’-nucleotidase at week 14, although increases occurred on day 5 in females at ≥20 mg/kg/day and on day 21 in males and females at 80, 170, and/or 320 mg/kg/day. As discussed by NTP (2004a), increases in ALT and SDH are specific markers of hepatocellular necrosis or increased cell membrane permeability (leakage) in rodents; increases in bile acids are markers of cholestasis, impaired hepatocellular function, or hepatocellular injury; increases in ALP and 5’-nucleotidase are other markers of cholestasis; and decreases in serum cholesterol could be indicative of liver dysfunction (impaired cholesterol biosynthesis). The LOAEL for serum chemistry effects is 170 mg/kg/day because the magnitude of the changes in serum ALT, SDH, and cholesterol at 80 mg/kg/day were less than 2-fold different from controls and not considered to be biologically significant.

Histological evaluation presented further evidence of the liver as the primary target of 1,1,2,2-tetrachloroethane toxicity; a summary of histological changes is presented in Table A-2. Hepatic cytoplasmic vacuolization was noted in males exposed to 20 mg/kg/day or more and females exposed to 40 mg/kg/day or more. Although the incidence of this alteration was high in affected groups, severity was only minimal-to-mild and did not increase with dose. Females exposed to 80 mg/kg/day showed an increase in the incidence of hepatocyte hypertrophy, which increased in severity and incidence with increasing exposure level; similar results were seen in males, but were not statistically significant below 170 mg/kg/day. At ≥170 mg/kg/day, additional effects in the liver in both sexes were hepatocyte necrosis, pigmentation, mitotic alteration and mixed cell foci, and bile duct hyperplasia. Pigmentation of the spleen was increased in male rats exposed to ≥80 mg/kg/day and in female rats exposed to ≥170 mg/kg/day. Other histological effects included high incidences (70–100%) of atrophy in the spleen (red pulp and lymphoid follicle) of both sexes at 320 mg/kg/day, bone (metaphysis) and bone marrow in females at ≥170 mg/kg/day and males at 320 mg/kg/day, and male and female reproductive tissues at 320 mg/kg/day. The reductions in body weight gain at 170 mg/kg/day and body weight losses at 320 mg/kg/day may have contributed to the atrophy of the bone, bone marrow, and reproductive tissues.

Table A-2 Incidences of Selected Histopathological Lesions in Rats Exposed to 1,1,2,2-Tetrachloroethane in the Diet for 14 Weeks

End point | Vehicle control | Dose (mg/kg/day)
End point | Vehicle control | 20 | 40 | 80 | 170 | 320
Males (10/group)^a^
Hepatocyte cytoplasmic vacuolization | 0 | 7^b^ (1.3) | 9^b^ (2.0) | 10^b^ (1.9) | 8^b^ (1.4) | 0
Hepatocyte hypertrophy | 0 | 0 | 0 | 1 (1.0) | 9^b^ (1.3) | 10^b^ (3.2)
Hepatocyte necrosis | 0 | 0 | 0 | 0 | 8^b^ (1.0) | 10^b^ (1.6)
Hepatocyte pigmentation | 0 | 0 | 0 | 0 | 7^b^ (1.0) | 10^b^ (1.9)
Hepatocyte mitotic alteration | 0 | 0 | 0 | 0 | 0 | 6^b^ (2.0)
Mixed cell foci | 0 | 0 | 0 | 0 | 3 | 5^b^
Bile duct hyperplasia | 0 | 0 | 0 | 0 | 0 | 10^b^ (1.7)
Spleen pigmentation | 0 | 0 | 1 (10) | 9^b^ (1.0) | 9^b^ (1.0) | 9^b^ (1.6)
Spleen red pulp atrophy | 0 | 0 | 0 | 0 | 5^b^ (1.0) | 9^b^ (1.4)
Spleen lymphoid follicle atrophy | 0 | 0 | 0 | 0 | 0 | 5^b^ (1.0)
Females (10/group)^a^
Hepatocyte cytoplasmic vacuolization | 0 | 0 | 10^b^ (1.7) | 10^b^ (2.2) | 4^b^ (1.3) | 0
Hepatocyte hypertrophy | 0 | 0 | 0 | 4^b^ (1.0) | 10^b^ (1.7) | 10^b^ (2.8)
Hepatocyte necrosis | 0 | 0 | 0 | 1 (10) | 7^b^ (1.0) | 10^b^ (1.1)
Hepatocyte pigmentation | 0 | 0 | 0 | 0 | 10^b^ (1.3) | 10^b^ (2.0)
Hepatocyte mitotic alteration | 0 | 0 | 0 | 0 | 3 (2.0) | 10^b^ (1.9)
Mixed cell foci | 0 | 0 | 0 | 0 | 8^b^ | 1
Bile duct hyperplasia | 0 | 0 | 0 | 0 | 5^b^ (1.0) | 10^b^ (1.9)
Spleen pigmentation | 1 (10) | 0 | 0 | 4 (1.0) | 8^b^ (1.1) | 8^b^ (1.3)
Spleen, red pulp atrophy | 0 | 0 | 0 | 0 | 0 | 9^b^ (1.6)
Spleen lymphoid follicle atrophy | 0 | 0 | 0 | 0 | 0 | 3 (1.0)

a Values represent number of animals with the lesion, with the severity score in parenthesis; severity grades are as follows: 1=minimal, 2=mild, 3=moderate, 4=severe.

b Significantly different (p<0.01) from vehicle control group by the Fisher Exact Test.

Source: NTP 2004a

Reproductive effects in the males included statistically significant reductions in sperm motility at ≥40 mg/kg/day (18–22% less than vehicle controls), reductions in absolute epididymis weight at ≥80 mg/kg/day and absolute left cauda epididymis weight at 170 mg/kg/day (relative organ weights not reported), and increases in incidences (90–100%) of minimal to moderate atrophy of the prostate gland, seminal vesicle, and testicular germinal epithelium at 320 mg/kg/day. Reproductive effects in the females included statistically significant increases in incidences (70–100%) of minimal to mild uterine atrophy at ≥170 mg/kg/day, clitoral gland atrophy at 320 mg/kg/day, and ovarian interstitial cell cytoplasmic alterations at 320 mg/kg/day. The vaginal cytology evaluations indicated that the females in the 170 mg/kg/day group (320 mg/kg/day not evaluated) spent more time in diestrus and less time in proestrus, estrus, and metestrus than did the vehicle controls. The body weight loss at 320 mg/kg/day and reduced body weight gain at the lower dose levels could have contributed to the atrophy and other effects in both sexes. The LOAEL for male rat reproductive effects is 320 mg/kg/day based on atrophy in the prostate gland, seminal vesicle, and testicular germinal epithelium. The effects in males at lower doses are not judged to be adverse, indicating that the male reproductive NOAEL is 170 mg/kg/day. In particular, the male reproductive organ weight decreases at 80 and 170 mg/kg/day are not considered adverse due to a lack of accompanying histopathology. The reductions in sperm motility at ≥40 mg/kg/day are not considered adverse because the decreases are small, not dose-related, not accompanied by decreased sperm counts, and of unclear reproductive significance. The LOAEL for female rat reproductive effects is 170 mg/kg/day based on uterine atrophy and estrus cycle alterations; the corresponding NOAEL is 80 mg/kg/day.

In summary, this study provides evidence that the liver was the primary target of 1,1,2,2-tetrachloroethane toxicity in rats. At the lowest dose tested, 20 mg/kg/day, there was a significant increase in the incidence of hepatic cytoplasmic vacuolization in males; this minimal effect, which did not increase in severity with dose, was not considered adverse by NTP (2004a). At 40 mg/kg/day, significant increases in relative liver weights were observed. Hepatocellular hypertrophy, spleen pigmentation, and decreases in body weight gain (<10%) were observed at 80 mg/kg/day, although these changes were generally of minimal severity or adaptive in nature. Increases in serum ALT and SDH and decreases in serum cholesterol also occurred at ≥80 mg/kg/day, but the magnitudes of these changes were biologically significant only at ≥170 mg/kg/day. Other effects that occurred at 170 and 320 mg/kg/day included increases in serum ALP and bile acids, hepatocyte necrosis, bile duct hyperplasia, hepatocellular mitotic alterations, foci of cellular alterations, and liver pigmentation. This study identified a NOAEL of 80 mg/kg/day and a LOAEL of 170 mg/kg/day for systemic toxicity based on adverse liver-related serum chemistry changes and histological manifestations of hepatocellular damage. This LOAEL is lower than or equal to the LOAELs for reproductive effects in males (320 mg/kg/day) and females (170 mg/kg/day). A LOAEL for neurotoxicity was not identified because there were no clinical signs of neurotoxicity or exposure-related findings in the FOB at doses as high as 80 mg/kg/day (highest tested dose in the FOB). These findings suggest that the nervous system is less sensitive than the liver for intermediate-duration dietary exposure.

[underlined: Dose and end point used for MRL derivation]:

[ ] NOAEL [ ] LOAEL [X] BMDL

Based on benchmark dose analysis of dose-response data for various liver effects, a BMDL_10_ of 53.88 mg/kg/day for hepatocyte necrosis was selected as the point of departure for the MRL. The BMD analysis and basis for selection of the point of departure are presented in the last section of this worksheet.

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Average daily doses were reported by the investigators.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable (ad libitum dietary exposure).

[underlined: Other additional studies or pertinent information that lend support to this MRL]: The NTP (2004a) study also tested mice that were exposed to 1,1,2,2-tetrachloroethane in the diet for 14 weeks. As detailed below, this study found that the mice were less sensitive than the rats, as reflected by the liver toxicity findings, which identified LOAELs and NOAELs that were higher in the mice (300 and 200 mg/kg/day) than in the rats (170 and 80 mg/kg/day). Groups of 10 male and 10 female B6C3F1 mice were exposed to diets containing 0, 589, 1,120, 2,300, 4,550, or 9,100 ppm of microencapsulated 1,1,2,2-tetrachloroethane for 14 weeks. The reported average daily doses were 0, 100, 200, 370, 700, or 1,360 mg/kg/day for males and 80, 160, 300, 600, or 1,400 mg/kg/day for females; vehicle and untreated control groups were used for each sex. End points evaluated throughout the study included clinical signs, body weight, and feed consumption. Clinical chemistry (10 indices) was assessed at the end of the study; hematology evaluations and urinalyses were not performed. Necropsies were conducted on all animals and selected organs (liver, heart, right kidney, lung, right testis, and thymus) were weighed. Comprehensive histological examinations were performed on untreated control, vehicle control, and high dose groups. Tissues examined in the lower dose groups were limited to the liver, spleen, and thymus in both sexes, preputial gland in males, and lungs in females. FOBs (21 parameters) were performed on mice in both control and 160/200, 300/370, and 600/700 mg/kg/day groups during weeks 4 and 13. Sperm motility, vaginal cytology, estrous cycle length, and percentage of time spent in the various estrus stages were evaluated in both control and 160/200, 600/700, and 1,360/1,400 mg/kg/day groups.

All mice survived to the end of the study. A clinical sign of thinness was observed at 300/370 mg/kg/day (3/10 males, 1/10 females), 600/700 mg/kg/day (9/10 males, 2/10 females), and 1,360/1,400 mg/kg/day (10/10 males, 10/10 females). Final body weights were significantly lower than vehicle controls in male mice at 370, 700, and 1,360 mg/kg/day (12, 16, and 33% reduced, respectively) and female mice at 300, 600, and 1,400 mg/kg/day (4, 10, and 11% reduced, respectively) (Table A-3). Feed consumption was slightly less than controls in males at ≥700 mg/kg/day, but similar to controls in females. Significant increases in absolute and relative liver weights were observed in the male mice exposed to 200 mg/kg/day or higher and in female mice exposed to 80 mg/kg/day or higher (Table A-3). Other organ weight changes (increased kidney weights in males at ≥370 mg/kg/day and increased thymus weights in both sexes at 1,360/1,400 mg/kg/day) were considered to be secondary to the body weight changes. Results of the FOBs showed no exposure-related neurotoxicity.

Table A-3 Body Weight, Liver Weight, and Selected Clinical Chemistry Changes in Mice Exposed to Microencapsulated 1,1,2,2-Tetrachloroethane in the Diet for14 Weeks^a^

End point | Vehicle control | Dose (mg/kg/day)
End point | Vehicle control | 100 | 200 | 370 | 700 | 1,360
Males (10/group)
Body weight (g) | 30.1±0.6 | 30.6±0.6 | 30.0±0.3 | 26.5±0.4^b^ | 25.2±0.2^b^ | 23.1±0.5^b^
Liver weight
absolute (g) | 1.47±0.02 | 1.56±0.04 | 1.70±0.02^b^ | 1.61±0.04^b^ | 1.53±0.05 | 1.56±0.04
relative (%) | 48.84±1.17 | 50.94±0.93 | 56.82±0.63^b^ | 60.63±1.20^b^ | 60.71±1.76^b^ | 67.43±1.83^b^
Serum total protein (g/dL) | 5.4±0.1 | 5.2±0.1 | 5.1±0.1^b^ | 5.1±0.1^b^ | 5.1±0.1^b^ | 5.1±0.1^b^
Serum cholesterol (mg/dL) | 131±7 | 125±4 | 94±3^b^ | 110±5 | 112±4 | 126±5
ALT (IU/L) | 66±8 | 62±19 | 74±8 | 207±18^b^ | 172±18^b^ | 296±24^b^
ALP (IU/L) | 85±2 | 78±2 | 89±2 | 130±3^b^ | 143±7^b^ | 184±11^b^
SDH (IU/L) | 55±3 | 53±2 | 76±3^b^ | 288±20^b^ | 288±29^b^ | 448±25^b^
5’-Nucleo-tidase (IU/L) | 18±1 | 16±1 | 18±0 | 30±2^b^ | 37±3^b^ | 62±7^b^
Bile acids (μmol/L) | 25.3±1.2 | 22.8±1.5 | 24.8±0.6 | 56.5±5.1^b^ | 63.3±7.5^b^ | 108.7±8.1^b^
Females (10/group)
Body weight (g) | 24.3±0.5 | 24.2±0.2 | 24.3±0.6 | 23.3±0.4 | 21.7±0.2^b^ | 21.5±0.6^b^
Liver weight
absolute (g) | 1.05±0.03 | 1.16±0.02^b^ | 1.36±0.06^b^ | 1.34±0.04^b^ | 1.28±0.03^b^ | 1.39±0.05^b^
relative (%) | 43.26±1.05 | 47.90±0.85^b^ | 55.54±1.17^b^ | 57.39±0.84^b^ | 58.73±1.23^b^ | 64.42±1.14
Serum total protein (g/dL) | 5.6±0.1 | 5.6±0.1 | 5.5±0.0 | 5.4±0.1^b^ | 5.4±0.0^b^ | 5.1±0.1^b^
Serum cholesterol (mg/dL) | 109±2 | 109±3 | 85±3^b^ | 68±2^b^ | 64±3^b^ | 92±4^b^
ALT (IU/L) | 34±5 | 50±15 | 65±5^b^ | 189±33^b^ | 197±21^b^ | 351±35^b^
ALP (IU/L) | 131±5 | 126±2 | 139±5 | 150±3^b^ | 161±7^b^ | 195±6^b^
SDH (IU/L) | 36±1 | 44±3^b^ | 76±4^b^ | 197±15^b^ | 243±23^b^ | 461±59^b^
5’-Nucleo-tidase (IU/L) | 59±3 | 71±2 | 84±5^b^ | 62±2 | 62±3 | 83±4^b^
Bile acids (μmol/L) | 27.2±1.2 | 26.1±1.9 | 30.9±1.1^b^ | 44.2±3.9^b^ | 51.5±3.6^b^ | 101.7±12.0^b^

a Mean±standard error.

b Statistically significantly different from control value.

ALP = alkaline phosphatase; ALT = alanine aminotransferase; SDH = sorbitol dehydrogenase

Source: NTP 2004a

Clinical chemistry findings in the mice are summarized in Table A-3 and included statistically significant decreases in serum total protein in males at ≥200 mg/kg/day, serum total protein in females at ≥300 mg/kg/day, and serum albumin in females at 1,400 mg/kg/day. Decreased serum albumin could not fully account for the decreased total protein concentrations, suggesting that other factors (e.g., changes in other protein fractions, hydration status, and/or hepatic function) contributed to the hypoproteinemia (NTP 2004a). Other serum chemistry changes were indicative of dose-related liver effects beginning at 160 mg/kg/day; these included statistically significant increased SDH in both sexes at ≥160/200 mg/kg/day, decreased serum cholesterol in females at ≥160 mg/kg/day, increased ALT and total bile acids in females at ≥160 and males at ≥370 mg/kg/day, increased ALP in both sexes at 300/370 mg/kg/day, and increased 5’-nucleotidase in males at ≥370 mg/kg/day. As previously discussed for the rat study, these serum indices are markers of hepatocellular damage, cholestasis, and/or impaired hepatic function (NTP 2004a). The magnitudes of the serum chemistry changes were biologically significant (e.g., greater than 2-fold increases in serum ALT and SDH) at ≥300 mg/kg/day in females and ≥370 mg/kg/day in males.

Histopathological findings are consistent with the serum chemistry data in indicating that the liver is the most sensitive target of 1,1,2,2-tetrachloroethane toxicity in the mice. As summarized in Table A-4, minimal hepatocyte hypertrophy was observed at ≥160 mg/kg/day in females and ≥200 mg/kg/day in males. This effect is likely to be an adaptive non-adverse hepatic response. Degenerative and other adverse liver lesions, including necrosis, pigmentation, and bile duct hyperplasia, occurred at ≥300 mg/kg/day in females and ≥370 mg/kg/day in males. Other histological findings included increased incidences of preputial gland atrophy in the 100, 700, and 1,360 mg/kg/day male groups (Table A-4), but this effect was not clearly dose-related and is possibly associated with decreased body weight gain. Based on the adverse serum chemistry and histopathological changes at 300 mg/kg/day and higher doses, this study identifies a LOAEL of 300 mg/kg/day for liver toxicity in mice; the corresponding NOAEL is 200 mg/kg/day.

Table A-4 Incidences of Selected Histopathological Lesions in Mice Exposed to Microencapsulated 1,1,2,2-Tetrachloroethane in the Diet for14 Weeks

End point | Vehicle control | Dose (mg/kg/day)
End point | Vehicle control | 100 | 200 | 370 | 700 | 1,360
Males (10/group)^a^
Hepatocyte hypertrophy | 0 | 0 | 7^b^ (1.0) | 10^b^ (2.2) | 10^b^ (2.8) | 10^b^ (3.1)
Hepatocyte necrosis | 0 | 0 | 1 (2.0) | 8^b^ (1.1) | 8^b^ (1.0) | 9^b^ (1.0)
Liver focal pigmentation | 0 | 0 | 0 | 10^b^ (1.2) | 10^b^ (1.4) | 8^b^ (1.3)
Bile duct hyperplasia | 0 | 0 | 0 | 7^b^ (1.4) | 9^b^ (1.3) | 10^b^ (2.0)
Preputial gland atrophy | 0 | 4^b^ (2.0) | 2 (1.0) | 0 | 4^b^ (2.5) | 5^b^ (2.2)
End point | Vehicle control | Dose (mg/kg/day)
End point | Vehicle control | 80 | 160 | 300 | 600 | 1,400
Females (10/group)^a^
Hepatocyte hypertrophy | 0 | 2 (1.5) | 9^b^ (1.0) | 10^b^ (1.9) | 10^b^ (2.5) | 10^b^ (3.0)
Hepatocyte necrosis | 0 | 0 | 0 | 3 (1.0) | 7^b^ (1.0) | 4^b^ (1.0)
Liver focal pigmentation | 0 | 0 | 2 (1.0) | 9^b^ (1.0) | 8^b^ (1.0) | 7^b^ (1.1)
Bile duct hyperplasia | 0 | 0 | 0 | 8^b^ (1.0) | 10^b^ (1.4) | 10^b^ (2.0)

a Values represent number of animals with the lesion, with the severity score in parenthesis; severity grades are as follows: 1=minimal, 2=mild, 3=moderate, 4=severe.

b Significantly different from vehicle control group.

Source: NTP 2004a

Additional information on the intermediate-duration oral toxicity of 1,1,2,2-tetrachloroethane is available from a 21-day gavage study in rats (NTP 1996), a 16-day gavage study in mice (NTP 1993d), 6-week gavage studies in rats and mice (NCI 1978), and 15-day diet studies in rats and mice (NTP 2004a). These studies are mainly dose range-finding studies that used small numbers of animals and had limited or no evaluations of clinical chemistry and histology. Key findings include reduced body weight gain in rats exposed to 100 mg/kg/day by gavage for 6 weeks (NCI 1978) or 300 mg/kg/day in the diet for 15 days (NTP 2004a), cytoplasmic vacuolation in the liver at 104 mg/kg/day and clinical signs of neurotoxicity and mortality at 208 mg/kg/day in rats exposed by gavage for 21 days (NTP 1996), and hepatocellular degeneration in mice exposed to 337.5 mg/kg/day by gavage for 16 days (NTP 1993d) or 599 mg/kg/day in the diet for 15 days (NTP 2004a). The lowest LOAELs in these studies were 100–104 mg/kg/day for reduced body weight gain and hepatocyte cytoplasmic vacuolation in rats exposed by gavage (NCI 1978; NTP 1996) and 337.5 mg/kg/day for hepatocellular degeneration in mice exposed by gavage (NTP 1993d). The NTP (2004a) 14-week dietary study is the best basis for MRL derivation because it tested wider ranges of doses and varieties of end points, and identified lower LOAELs, than the other intermediate-duration studies.

Potential points of departure for the intermediate-duration oral MRL were derived by BMD analysis of the NTP (2004a) rat liver data in Table A-5. All available dichotomous models in the EPA Benchmark Dose Software (BMDS version 1.3.2) were fit to the incidence data for hepatocyte necrosis. The continuous-variable models in the software were applied to the data for changes in relative liver weight and serum ALT, SDH, bile acids, and cholesterol.

Table A-5 Selected Liver Effects in Rats Exposed to 1,1,2,2-Tetrachloroethanein the Diet for 14 weeks

End point | Dose (mg/kg/day)
End point | 0 | 20 | 40 | 80 | 170 | 320
Males (10/group)
Liver weight
relative (%) | 34.79±0.42 | 36.72±0.44 | 41.03±0.85^b^ | 45.61±0.52^b^ | 44.68±0.45^b^ | 52.23±1.42^b^
Hepatocyte necrosis | 0 | 0 | 0 | 0 | 8^b^ | 10^b^
Serum ALT (IU/L) | 48±2 | 49±2 | 53±2 | 69±3^b^ | 115±8^b^ | 292±18^b^
Serum SDH (IU/L) | 23±1 | 27±1^b^ | 26±2 | 31±1^b^ | 47±2^b^ | 74±4^b^
Bile acids (μmol/L) | 29.2±2.9 | 27.5±2.7 | 27.2±2.7 | 35.9±3.9 | 92.0±16.6^b^ | 332.4±47.4^b^
Females (10/group)
Liver weight
relative (%) | 35.07±0.56 | 36.69±0.36 | 37.84±0.51^b^ | 44.20±0.27^b^ | 48.03±0.89^b^ | 58.40±1.42^b^
Hepatocyte necrosis | 0 | 0 | 0 | 1 | 7^b^ | 10^b^
Serum ALT (IU/L) | 46±2 | 42±1 | 41±2 | 49±2 | 112±7^b^ | 339±18^b^
Serum SDH (IU/L) | 27±1 | 27±1 | 28±2 | 25±1 | 45±3^b^ | 82±3^b^
Bile acids (μmol/L) | 37.0±7.1 | 46.6±6.5 | 39.1±5.6 | 36.3±3.9 | 39.3±7.9 | 321.5±50.6^b^
Serum cholesterol (mg/dL) | 104±4 | 105±3 | 98±1 | 81±2^b^ | 64±3^b^ | 55±3^b^

a Mean±standard error.

b Statistically significantly different from control value.

ALT = alanine aminotransferase; SDH = sorbitol dehydrogenase

Source: NTP 2004a

For the incidence data, predicted doses associated with 30, 20, 10, 5, and 1% extra risks were calculated as possible alternative BMRs for the best fitting model. Conventionally, a 10% extra risk has served as a point of departure for MRL determination. However, for a study that examined only 10 animals per group, the limit of detection is above the 10% level, likely in the 20–30% range. For the continuous data, the BMDs and the 95% lower confidence limits (BMDLs) calculated are estimates of the doses associated with a change of 1 standard deviation from the control. Predicted doses associated with an increase of 100% (i.e., 2-fold) were also calculated for the best fitting model for the changes in liver enzymes (ALT, SDH) in the serum, as an increase of this magnitude is sometimes considered to be an indicator of clinical significance for these effects. A summary of the predicted BMDs and BMDLs for all of the end points is shown in Table A-6.

Table A-6 Summary of BMD Model Predictions for Rats Exposed to 1,1,2,2-Tetrachloroethane in the Diet for 14 Weeks (Best Fitting Models)

End point | BMR | BMD (mg/kg/day) | BMDL (mg/kg/day)
Males
Hepatocyte necrosis | 10% extra risk | 139.31 | 77.95
Hepatocyte necrosis | 1% extra risk | 121.94 | 46.26
Hepatocyte necrosis | 5% extra risk | 133.65 | 66.47
Hepatocyte necrosis | 20% extra risk | 145.73 | 92.04
Hepatocyte necrosis | 30% extra risk | 150.16 | 102.14
Relative liver weight | 1 control standard deviation | No adequate fit to the data
Serum ALT | 1 control standard deviation | 38.23 | 26.56
Serum ALT | 100% relative deviation | 134.06 | 121.35
Serum SDH | 1 control standard deviation | 36.71 | 25.13
Serum SDH | 100% relative deviation | 179.61 | 152.27
Bile acids | 1 control standard deviation | 72.45 | 57.17
Females
Hepatocyte necrosis | 10% extra risk | 82.89 | 53.88
Hepatocyte necrosis | 1% extra risk | 51.02 | 22.51
Hepatocyte necrosis | 5% extra risk | 70.55 | 40.85
Hepatocyte necrosis | 20% extra risk | 99.76 | 72.51
Hepatocyte necrosis | 30% extra risk | 113.30 | 87.38
Relative liver weight | 1 control standard deviation | No adequate fit to the data
Serum ALT | 1 control standard deviation | No adequate fit to the data
Serum SDH | 1 control standard deviation | No adequate fit to the data
Bile acids | 1 control standard deviation | 216.74 | 177.00
Serum cholesterol | 1 control standard deviation | No adequate fit to the data

ALT = alanine aminotransferase; BMD = benchmark dose; BMDL = lower confidence limit (95%) on the benchmark dose; BMR = benchmark response; SDH = sorbitol dehydrogenase

Source: NTP 2004a

The lowest BMDLs were calculated for the male rat serum ALT and SDH data using 1 standard deviation below the control mean as the BMR. The BMDLs for serum ALT (26.56 mg/kg/day) and serum SDH (25.13 mg/kg/day) are approximately half of the BMDL of 53.88 mg/kg/day calculated using the female rat hepatocyte necrosis incidence data and a BMR of 10%. The BMDLs for the serum enzyme changes appear to be overly conservative predictions that have questionable biological plausibilty because they are substantially below the study NOAEL of 80 mg/kg/day. Effects occurring at the NOAEL included increases in serum ALT and SDH that were not biologically significant and hepatocyte necrosis in 1/10 females. The BMDL of 53.88 mg/kg/day for hepatocyte necrosis was selected as the point of departure for the MRL because it is reasonably consistent with the observed findings. The intermediate-duration oral MRL of 0.5 mg/kg/day was derived by dividing the BMDL by a composite uncertainty factor of 100 (10 for extrapolation from humans and 10 for human variability).

#### Details of Benchmark Dose Analysis for the Intermediate-duration Inhalation MRL

##### Hepatocyte necrosis

All available dichotomous models in the EPA Benchmark Dose Software (BMDS version 1.3.2) were fit to the incidence data for hepatocyte necrosis in male and female rats (Table A-5). Predicted doses associated with 30, 20, 10, 5, and 1% extra risks were calculated for the best fitting models.

As assessed by the chi-square goodness-of-fit test, several models in the software provided adequate fits to the data for the incidence of hepatocyte necrosis in male rats (x^2^ p-value ≥0.1) (Table A-2). Comparing across models, a better fit is indicated by a lower Akaike’s Information Criteria value (AIC) (EPA 2000). The log-logistic model was determined to be the best-fitting model, as indicated by the AIC for the male rat data (Table A-7, Figure A-1), and the gamma model was determined to be the best fit to the female data (Table A-8, Figure A-2). Benchmark doses (BMDs and BMDLs) associated with an extra risk of 10% were calculated for all models. Alternative BMRs of 1, 5, 20, and 30% were calculated from the best fitting model for each data set. These are shown in Table A-6.

Table A-7 Goodness of Fit Statistics and BMD10s and BMDL10s from Models Fit to Incidence Data for Hepatocyte Necrosis in Male Rats Exposed to 1,1,2,2-Tetrachloroethane in the Diet for 14 Weeks

Model | Degrees of freedom | X^2^ test statistic | X^2^ p-value^a^ | AIC | BMD_10_ (mg/kg/day) | BMDL_10_ (mg/kg/day)
Gamma^d^ | 5 | 12.30 | 0.9995 | 12.30 | 102.95 | 74.23
Logistic | 4 | 0.00 | 1.0000 | 14.01 | 154.00 | 81.87
Log-Logistic^b,e^ | 5 | 0.00 | 1.0000 | 12.01 | 139.31 | 77.95
Multistage^c,f^ | 4 | 0.86 | 0.9304 | 13.59 | 88.60 | 65.67
Probit | 4 | 0.00 | 1.0000 | 14.01 | 140.74 | 78.18
Log-probit^e^ | 4 | 0.00 | 1.0000 | 14.01 | 133.48 | 76.77
Quantal-linear | 5 | 12.79 | 0.0255 | 32.82 | 20.50 | 13.77
Quantal-quadratic | 5 | 4.56 | 0.4718 | 19.68 | 53.11 | 41.50
Weibull^d^ | 4 | 0.00 | 1.0000 | 14.01 | 144.11 | 76.51

a Values <0.1 fail to meet conventional goodness-of-fit criteria

b Best-fitting model

c 2-degree polynomial; lowest degree polynomial with adequate fit

d Power restricted to >=1

e Slope restricted to >=1

f Betas restricted to >=0

AIC = Akaike’s Information Criteria; BMD = benchmark dose; BMDL = lower confidence limit (95%) on the benchmark dose

Source: NTP 2004a

Figure A-1 Observed and Predicted Incidences of Hepatocyte Necrosis in Male Rats Exposed to 1,1,2,2-Tetrachloroethane in the Diet for 14 Weeks^*^ * BMDs and BMDLs indicated are for a 10% extra risk and are in units of mg/kg/day.

Source: NTP 2004a

Table A-8 Goodness of Fit Statistics and BMD10s and BMDL10s from Models Fit to Incidence Data for Hepatocyte Necrosis in Female Rats Exposed to 1,1,2,2-Tetrachloroethane in the Diet for 14 Weeks

Model | Degrees of freedom | X^2^ test statistic | X^2^ p-value^a^ | AIC | BMD_10_ (mg/kg/day) | BMDL_10_ (mg/kg/day)
Gamma^b,d^ | 4 | 0.11 | 0.9986 | 22.89 | 82.89 | 53.88
Logistic | 4 | 0.47 | 0.9765 | 23.39 | 92.95 | 62.34
Log-Logistic^e^ | 4 | 0.36 | 0.9853 | 23.30 | 84.90 | 56.41
Multistage^c,f^ | 4 | 0.14 | 0.9978 | 22.95 | 84.75 | 49.88
Probit | 4 | 0.24 | 0.9933 | 23.08 | 87.79 | 58.48
Log-probit ^e^ | 4 | 0.20 | 0.9953 | 23.03 | 82.69 | 56.27
Quantal-linear | 5 | 8.84 | 0.1156 | 34.83 | 20.87 | 14.04
Quantal-quadratic | 5 | 1.80 | 0.8755 | 23.60 | 54.34 | 42.71
Weibull^d^ | 4 | 0.12 | 0.9983 | 22.92 | 84.37 | 51.46

a Values <0.1 fail to meet conventional goodness-of-fit criteria

b Best-fitting model

c 2-degree polynomial; lowest degree polynomial with adequate fit

d Power restricted to >=1

e Slope restricted to >=1

f Betas restricted to >=0

AIC = Akaike’s Information Criteria; BMD = benchmark dose; BMDL = lower confidence limit (95%) on the benchmark dose

Source: NTP 2004a

Figure A-2 Observed and Predicted Incidences of Hepatocyte Necrosis in Female Rats Exposed to 1,1,2,2-Tetrachloroethane in the Diet for 14 Weeks^*^ * BMDs and BMDLs indicated are for a 10% extra risk and are in units of mg/kg/day.

Source: NTP 2004a

#### Continuous Data

Available continuous-variable models in the EPA Benchmark Dose Software (linear, polynomial, power, and Hill models; BMDS version 1.3.2) were fit to the data shown in Table A-5, for changes in relative liver weight and serum ALT, SDH, bile acids and cholesterol in male and female rats. The BMDs and the 95% lower confidence limits (BMDLs) calculated are estimates of the doses associated with a change of 1 standard deviation from the control. Predicted doses associated with an increase of 100% were also calculated for the changes in serum liver enzymes. For the continuous data, the simplest model (linear) was applied to the data first while assuming constant variance. If the data were consistent with the assumption of constant variance (p-value ≥0.1), then the fit of the linear model to the means was evaluated. If the linear model adequately fit the means (p-value ≥0.1), then it was selected as the model for BMD derivation. If the linear model did not adequately fit the means, then the more complex models were fit to the data while assuming constant variance. Among those providing adequate fit to the means (p-value ≥0.1), the one with the lowest AIC for the fitted model was selected for BMD derivation. If the test for constant variance was negative, the linear model was run again while applying the power model integrated into the BMDS to account for non-homogenous variance. If the non-homogenous variance model provided an adequate fit (p-value ≥0.1) to the variance data, then the fit of the linear model to the means was evaluated. If the linear model did not provide adequate fit to the means while the variance model was applied, then the polynomial, power, and Hill models were fit to the data and evaluated while the variance model was applied. Among those providing adequate fit to the means (p-value ≥0.1), the one with the lowest AIC for the fitted model was selected for BMD derivation. If the test for constant variance was negative and the non-homogenous variance model did not provide an adequate fit to the variance data, then the data set was considered not to be suitable for BMD modeling.

##### Relative liver weight

Statistical tests indicated that variances were not constant across exposure groups (this is reflected in the standard errors listed in Table A-5). The non-homogeneous variance model did not adequately fit the variance data for either males or females; therefore, there was no good fit to the data for change in relative liver weight in either male or female rats (Table A-9).

Table A-9 Model Predictions for Changes in Relative Liver Weight in Rats Exposed to 1,1,2,2-Tetrachloroethane in the Diet for 14 Weeks

Model | Variance p-value^a^ | Means p-value^b^ | BMD_1sd_ (mg/kg/day) | BMDL_1sd_ (mg/kg/day)
Male
Linear (constant variance) | <0.0001 | <0.0001 | 68.02 | 56.64
Linear (modeled variance) | 0.0255 | <0.0001 | 55.05 | 37.77
Female
Linear (constant variance) | <0.0001 | 0.0063 | 36.16 | 30.95
Linear (modeled variance) | 0.0076 | 0.0004 | 22.21 | 14.61

a Values <0.05 fail to meet conventional goodness-of-fit criteria

b Values <0.10 fail to meet conventional goodness-of-fit criteria

BMD = benchmark dose; BMDL = lower confidence limit (95%) on the benchmark dose

Source: NTP 2004a

##### Serum ALT

For the serum ALT data, the assumption of constant variance did not hold for either the male or female data. The non-homogeneous variance model was applied and provided adequate fit to the variance for both the male and female data. With the variance model applied, the linear model did not provide adequate fit to the means for either the male or female data. For the males, both the polynomial and power models provided adequate fit to the means while the variance model was applied. The AIC was slightly lower for the polynomial model, which was selected as the best fitting model. Doses associated with a 100% change from the control (2-fold) from the polynomial model were also calculated (Table A-10, Figure A-3). For the females, none of the models were able to provide adequate fit to the means while the variance model was applied.

Table A-10 Model Predictions for Changes in Serum ALT in Rats Exposed to 1,1,2,2-Tetrachloroethane in the Diet for 14 Weeks

Model | BMR | Variance p-value^a^ | Meansp-value^b^ | AIC | BMD (mg/kg/day) | BMDL (mg/kg/day)
Male
Linear (constant variance) | 1 sd | <0.0001 | <0.0001 | 484.88 | 43.91 | 37.37
Linear (modeled variance) | 1 sd | 0.7223 | <0.0001 | 412.89 | 12.72 | 10.07
Polynomial^c,d^ (modeled variance) | 1 sd | 0.7223 | 0.7302 | 367.955 | 38.23 | 26.56
Polynomial^c,d^ (modeled variance) | 100% | 0.7223 | 0.7302 | 367.955 | 134.06 | 121.35
Power^e^ (modeled variance) | 1 sd | 0.6731 | 0.7945 | 367.956 | 41.97 | 32.24
Hill^f^ (modeled variance) | NA
Female
Linear (constant variance) | 1 sd | <0.0001 | <0.0001 | 511.01 | 44.94 | 38.22
Linear (modeled variance) | 1 sd | 0.1849 | <0.0001 | 447.29 | 17.59 | 13.50
Polynomial^g^ (modeled variance) | 1 sd | 0.1849 | <0.0001 | 370.32 | 49.47 | 45.00
Power^e^ (modeled variance) | 1 sd | 0.1782 | 0.0074 | 358.41 | 64.68 | 56.13
Hill^f^ (modeled variance) | NA

a Values <0.05 fail to meet conventional goodness-of-fit criteria

b Values <0.10 fail to meet conventional goodness-of-fit criteria

c Best-fitting model

d 2-degree polynomial; lowest degree polynomial with adequate fit

e Power restricted to >=1

f N restricted to >1

g 2-degree polynomial; no adequate fit with any polydegree

AIC = Akaike’s Information Criteria; BMD = benchmark dose; BMDL = lower confidence limit (95%) on the benchmark dose; NA = not available (BMD software could not generate a model output); sd = standard deviation

Source: NTP 2004a

Figure A-3 Changes in Serum ALT in Male Rats Exposed to 1,1,2,2-Tetrachloroethane in the Diet for 14 Weeks^*^ * BMDs and BMDLs indicated are associated with a change of 1 standard deviation from the control, and are in units of mg/kg/day.

Source: NTP 2004a

##### Serum SDH

For the serum SDH data, the assumption of constant variance did not hold for either the male or female data. The non-homogeneous variance model was applied and provided marginally adequate fit to the variance for both the male and female data. With the variance model applied, the linear model did not provide adequate fit to the means for either the male or female data. For the males, both the polynomial and power models provided adequate fit to the means while the variance model was applied. The AIC was slightly lower for the polynomial model, which was selected as the best fitting model. Doses associated with a 100% change from the control (2-fold) from the polynomial model were also calculated (Table A-11, Figure A-4). For the females, none of the models were able to provide adequate fit to the means while the variance model was applied.

Table A-11 Model Predictions for Changes in Serum SDH in Rats Exposed to 1,1,2,2-Tetrachloroethane in the Diet for 14 Weeks

Model | BMR | Variance p-value^a^ | Meansp-value^b^ | AIC | BMD (mg/kg/day) | BMDL (mg/kg/day)
Male
Linear (constant variance) | 1 sd | <0.0001 | 0.1889 | 291.96 | 41.70 | 35.55
Linear (modeled variance) | 1 sd | 0.0499 | 0.0471 | 274.89 | 23.86 | 19.11
Polynomial^c,d^ (modeled variance) | 1 sd | 0.0499 | 0.3259 | 270.72 | 36.70 | 25.13
Polynomial^c,d^ (modeled variance) | 100% | 0.0499 | 0.3259 | 270.72 | 179.61 | 152.27
Power^e^ (modeled variance) | 1 sd | 0.0499 | 0.3044 | 270.89 | 44.40 | 28.51
Hill^f^ (modeled variance) | NA
Female
Linear (constant variance) | 1 sd | <0.0001 | <0.0001 | 319.64 | 47.70 | 40.47
Linear (modeled variance) | 1 sd | 0.0429 | <0.0001 | 310.32 | 34.45 | 26.54
Polynomial^g^ (modeled variance) | 1 sd | 0.0429 | 0.0018 | 283.22 | 92.47 | 69.39
Power^e^ (modeled variance) | 1 sd | 0.0429 | 0.0018 | 285.20 | 90.68 | 70.92
Hill^f^ (modeled variance) | NA

a Values <0.05 fail to meet conventional goodness-of-fit criteria

b Values <0.10 fail to meet conventional goodness-of-fit criteria

c Best-fitting model

d 2-degree polynomial; lowest degree polynomial with adequate fit

e Power restricted to >=1

f N restricted to >1

g 2-degree polynomial; no adequate fit with any polydegree

AIC = Akaike’s Information Criteria; BMD = benchmark dose; BMDL = lower confidence limit (95%) on the benchmark dose; NA = not available (BMD software could not generate a model output); sd = standard deviation

Source: NTP 2004a

Figure A-4 Changes in Serum SDH in Male Rats Exposed to 1,1,2,2-Tetrachloroethane in the Diet for 14 Weeks^*^ * BMDs and BMDLs indicated are associated with a change of 1 standard deviation from the control, and are in units of mg/kg/day.

Source: NTP 2004a

##### Bile acids

For the serum bile acids data, the assumption of constant variance did not hold for either the male or female data. The non-homogeneous variance model was applied and provided adequate fit to the variance for both the male and female data. With the variance model applied, the Linear and Hill models did not provide adequate fit to the means for either the male or female data, and the Polynomial model did not provide adequate fit to the mean for the female data. For the males, both the Polynomial and Power models provided adequate fit to the means while the variance model was applied. The Power model was selected as the best fitting model for the male data because it had a slightly lower AIC than the Polynomial model (Table A-12, Figure A-5). For the females, the Power model was the only model that provided adequate fit to the means while the variance model was applied (Table A-12, Figure A-6).

Table A-12 Model Predictions for Changes in Bile Acids in Rats Exposed to 1,1,2,2-Tetrachloroethane in the Diet for 14 Weeks

Model | BMR | Variance p-value^a^ | Means p-value^b^ | AIC | BMD (mg/kg/day) | BMDL (mg/kg/day)
Male
Linear (constant variance) | 1sd | <0.0001 | 0.0013 | 577.11 | 79.44 | 61.93
Linear (modeled variance) | 1sd | 0.7661 | <0.0001 | 464.43 | 24.81 | 20.06
Polynomial^c^ (modeled variance) | 1sd | 0.7661 | 0.1194 | 428.95 | 58.37 | 49.57
Power^d,e^ (modeled variance) | 1sd | 0.7661 | 0.4582 | 427.70 | 72.45 | 57.17
Hill^f^ (modeled variance) | NA
Female
Linear (constant variance) | 1sd | <0.0001 | <0.0001 | 594.57 | 101.36 | 81.28
Linear (modeled variance) | 1sd | 0.4663 | <0.0001 | 576.14 | NA | 54.83
Polynomial^g^ (modeled variance) | 1sd | 0.4663 | <0.0001 | 487.96 | 149.50 | 106.40
Power^d,e^ (modeled variance) | 1sd | 0.4663 | 0.3751 | 466.68 | 216.74 | 177.00
Hill^f^ (modeled variance) | NA

a Values <0.05 fail to meet conventional goodness-of-fit criteria

b Values <0.10 fail to meet conventional goodness-of-fit criteria

c 2-degree polynomial; lowest degree polynomial with adequate fit

d Best-fitting model

e Power restricted to >=1

f N restricted to >1

g 2-degree polynomial; no adequate fit with any polydegree

AIC = Akaike’s Information Criteria; BMD = benchmark dose; BMDL = lower confidence limit (95%) on the benchmark dose; NA = not available (BMD software could not generate a model output)

Source: NTP 2004a

Figure A-5 Changes in Bile Acids in Male Rats Exposed to 1,1,2,2-Tetrachloroethane in the Diet for 14 Weeks^*^ * BMDs and BMDLs indicated are associated with a change of 1 standard deviation from the control, and are in units of mg/kg/day.

Source: NTP 2004a

Figure A-6 Changes in Bile Acids in Female Rats Exposed to 1,1,2,2-Tetrachloroethane in the Diet for 14 Weeks^*^ * BMDs and BMDLs indicated are associated with a change of 1 standard deviation from the control, and are in units of mg/kg/day.

Source: NTP 2004a

##### Serum cholesterol (females only)

Statistical tests indicated that variances were not constant across exposure groups (this is reflected in the standard deviations listed in Table A-5). The non-homogeneous variance model did not adequately fit the variance data; therefore, there was no good fit to the data for change in serum cholesterol in female rats (Table A-13).

Table A-13 Model Predictions for Changes in Serum Cholesterol in Female Rats Exposed to 1,1,2,2-Tetrachloroethane in the Diet for 14 Weeks

Model | Variance p-value^a^ | Means p-value^b^ | BMD_1sd_ (mg/kg/day) | BMDL_1sd_ (mg/kg/day)
Female
Linear (constant variance) | 0.0044 | <0.0001 | 63.66 | 53.24
Linear (modeled variance) | 0.0019 | <0.0001 | 56.37 | 39.96

a Values <0.05 fail to meet conventional goodness-of-fit criteria

b Values <0.10 fail to meet conventional goodness-of-fit criteria

BMD = benchmark dose; BMDL = lower confidence limit (95%) on the benchmark dose

Source: NTP 2004a

[underlined: Agency Contacts (Chemical Managers)]: Jessilynn Taylor, Henry Abadin, and Eugene Demchuk