# 9 REFERENCES

*Cited in text

Aalto M, Heppleston AG. 1984. Fibrogenesis by mineral fibres: An in-vitro study of the roles of the macrophage and fibre length. Br J Exp Pathol 65(1):91–99.6696832
ACGIH. 1992. Fibrous glass dust. American Conference of Government Industrial Hygienists. Cincinnati, OH.
ACGIH. 1998. Asbestos, all forms. American Conference of Government Industrial Hygienists. Cincinnati, OH.
*ACGIH. 2001. Synthetic vitreous fibers. Supplement to documentation of the threshold limit values and biological exposure indices. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
Adachi S, Kawamura K, Takemoto K. 2001. A trial on the quantitative risk assessment of man-made mineral fibers by the rat intraperitoneal administration assay using the JFM standard fibrous samples. Ind Health 39(2):168–174.11341547
*Adachi S, Takemoto K, Kimura K. 1991. Tumorigenicity of fine man-made fibers after intratracheal administrations to hamsters. Environ Res 54(1):52–73.2004637
*Adamson IYR, Bakowska J, Bowden DH. 1994. Mesothelial cell proliferation: A nonspecific response to lung injury associated with fibrosis. Am J Respir Cell Mol Biol 10:253–258.7509611
*Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
*Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
Afaq F, Abidi P, Matin R, . 1998. Activation of alveolar macrophages and peripheral red blood cells in rats exposed to fibers/particles. Toxicol Lett 99:175–182.9862283
*Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Federal Register 54(174):37618–37634.
Agency for Toxic Substances and Disease Registry. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary, and immune systems. Atlanta, GA. Subcommittee on Biomarkers of Organ Damage and Dysfunction, Atlanta, GA.
*Agency for Toxic Substances and Disease Registry. 2001. Toxicological profile for asbestos (Update). Department of Health and Human Services, Atlanta, GA.
Alam W. 1998. Manufactured mineral fibers. In: Hamilton & Hardy’s industrial toxicology. St Louis: Mosby Publishers, 571–573.
*Albin M, Engholm G, Hallin N, . 1998. Impact of exposure to insulation wool on lung function and cough in Swedish construction workers. Occup Environ Med 55:661–667.9930086
Alexander IC, Brown RC, Jubb GA, . 1994. Durability of ceramic and novel man-made mineral fibers. Environ Health Perspect 102:67–71.
*Altman PL, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
*American Thoracic Society. 1986. The diagnosis of nonmalignant diseases related to asbestos. Am Rev Resp Dis 134:363–368.3740660
*Andersen A, Langmark F. 1986. Incidence of cancer in the mineral-wool producing industry in Norway. Scand J Work Environ Health 12:72–77.3026038
*Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York: Marcel Dekker, Inc., 9–25.
*Andersen ME, Clewell HJ III, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
Antonsson A-B, Runmark S. 1987. Airborne fibrous glass and dust originating from worked reinforced plastics. Am Ind Hyg Assoc J 48(8):684–687.
Ares J. 1990. Exposure to non-asbestos refractory materials: Corrections to fiber counts for comparable risk assessment. Bull Environ Contam Toxicol 45:783–788.2279126
*ASTM. 1988. Standard test method for airborne asbestos concentration in workplace atmosphere-method D 4240-83. In: 1988 annual book of ASTM standards. Vol. 11.03. Atmospheric analysis, occupational safety and health. Philadelphia, PA: American Society for Testing and Materials, 300–308.
Aufderheide M, Riebe-Imre M, Straub M, . 1994a. Cellular effects of mineral fibers. In: Dungworth DL, Mauderly JL, Oberdorster G, eds. Toxic and carcinogenic effects of solid particles in the respiratory tract. Washington, DC: ILSI Press, 575–580.
Aufderheide M, Riebe-Imre M, Straub M, . 1994b. Differences in the biological effects of crocidolite asbestos and two glass fibres on epithelial lung cells. Exp Toxicol Pathol 45(8):467–472.8054823
Balzer JL. 1976. Environmental data; Airborne concentrations found in various operations. Occupational exposure to fibrous glass. Proceedings of a symposium sponsored by NIOSH, April 1976.
*Balzer JL, Cooper WC, Fowler DP. 1971. Fibrous glass-lined air transmission systems: An assessment of their environmental effects. Am Ind Hyg Assoc J 32:512–518.4946492
*Barchowsky A, Lannon BM, Elmore LC, . 1997. Increased focal adhesion kinase- and urokinase-type plasminogen activator receptor-associated cell signaling in endothelial cells exposed to asbestos. Environ Health Perspect 105:1131–1137.9400712
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Baron PA. 1996. Application of the thoracic sampling definition to fiber measurement. Am Ind Hyg Assoc J 57(9):820–824.8865590
Baron PA. 2001. Measurement of airborne fibers: A review. Ind Health 39:39–50.11341557
*Bayliss DL, Dement JM, Wagoner JK, . 1976. Mortality patterns among fibrous glass production workers. Ann N Y Acad Sci 271:324–335.1069521
Beck EG, Holt PF, Manojlovic N. 1972. Comparison of effects on macrophage cultures of glass fibre, glass powder, and chrysotile asbestos. Br J Ind Med 29:280–286.4339803
Bellmann B, Konig H, Muhle H, . 1986. Chemical durability of asbestos and of man-made mineral fibres in vivo. J Aerosol Sci 17(3):341–345.
*Bellmann B, Muhle H, Creutzenberg O, . 2001. Effects of nonfibrous particles on ceramic fiber (RCF1) toxicity in rats. Inhal Toxicol 13(10):877–901.11696865
Bellmann B, Muhle H, Creutzenberg O, . 2003. Calibration study on subchronic inhalation toxicity of man-made vitreous fibers in rats. Inhal Toxicol 15:1147–1177.14515220
*Bellmann B, Muhle H, Kamstrup O, . 1994a. Investigation on the durability of man-made vitreous fibers in rat lungs. Environ Health Perspect Suppl 102(5):185–189.
*Bellmann B, Muhle H, Kamstrup O, . 1995. Investigation on the biodurability of chemically different stone wool fibres. Exp Toxicol Pathol 47(2–3):195–201.7580108
*Bellmann B, Muhle H, Pott F. 1994b. Investigation of the biodurability and carcinogenicity of different man-made mineral fibres. NATO ASI Ser H 85:299–304.
*Bender JR. 1993. Pulmonary effects of exposure to fine fiberglass: Irregular opacities and small airways obstruction. Br J Ind Med 50(4):381.
Bender JR, Hadley JG. 1994. Glass fiber manufacturing and fiber safety: The producer’s perspective. Environ Health Perspect 102(Suppl 6):37–40.
*Bendsoe N, Bjornberg A, Lowhagen G-B, . 1987. Glass fibre irritation and protective creams. Contact Dermatitis 17(2):69–72.2958234
*Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag, 3–7.
Bermudez E, Mangum JB, Moss OR, . 2003. Pleural dosimetry and pathobiological responses in rats and hamsters exposed subchronically to MMVF 10a fiberglass. Toxicol Sci 74:165–173.12773778
*Bernard A, Hermans C. 1997. Biomonitoring of early effects on the kidney or the lung. Sci Total Environ 199:205–211.9200865
Bernstein DM. 1993. An evaluation of the use of an inhalation model versus intraperitoneal injection model for the assessment in rats of the carcinogenicity of natural and man-made vitreous fibers. Zentralbl Arbeitsmed Arbeitsshutz Prophyl Ergon 43(4):120–128.
Bernstein DM, Chevalier J, Smith P. 2003. Comparison of calidria chrysotile asbestos to pure tremolite: Inhalation biopersistence and histopathology following short-term exposure. Inhal Toxicol 15:1387–1419.14648356
*Bernstein DM, Morscheidt C, Grimm H-G, . 1996. Evaluation of soluble fibers using the inhalation biopersistence model. A nine-fiber comparison. Inhal Toxicol 8:345–385.
*Bernstein DM, Morscheidt C, Tiesler H, . 1995. Evaluation of the biopersistence of commercial and experimental fibers following inhalation. Inhal Toxicol 7(7):1031–1058.
*Bernstein DM, Riego Sintes JM, Ersboell BK, . 2001b. Biopersistence of synthetic mineral fibers as a predictor of chronic inhalation toxicity in rats. Inhal Toxicol 13(10):823–849.11696863
*Bernstein DM, Riego Sintes JM, Ersboell BK, . 2001a. Biopersistence of synthetic mineral fibers as a predictor of chronic intraperitoneal injection tumor response in rats. Inhal Toxicol 13(10):851–875.11696864
Berrigan D. 2002. Respiratory cancer and exposure to man-made vitreous fibers: A systematic review. Am J Ind Med 42:354–362.12271483
Berry G. 1999. Models for mesothelioma incidence following exposure to fibers in terms of timing and duration of exposure and the biopersistence of the fibers. Inhal Toxicol 11:111–130.10380162
*Bertazzi PA, Zocchetti C, Riboldi L, . 1986. Cancer mortality of an Italian cohort of workers in man-made glass-fiber production. Scand J Work Environ Health 12(1):65–71.3798057
Bertrand R, Pezerat H. 1980. Fibrous glass: Carcinogenicity and dimensional characteristics. IARC Sci Publ 30:901–911.
Bignon J. 1983. Lung diseases and non-asbestos fibres. Eur J Respir Dis 64:397–402.
Bignon J. 1989. Mineral fibres in the non-occupational environment. In: Bignon J, Peto J, Saracci R, eds. Non-occupational exposure to mineral fibres. IARC Publication No. 90. Lyon, France.
Bignon J, Brochard P, Brown R, . 1995. Assessment of the toxicity of man-made fibres. A final report of a workshop held in Paris, France, 3-4, February 1994. Ann Occup Hyg 39(1):89–106.7702245
Bignon J, Monchaux G, Chameaud J, . 1983. Incidence of various types of thoracic malignancy induced in rats by intrapleural injection of 2 mg of various mineral dusts after inhalation of ^222^Ra. Carcinogenesis 4(5):621–628.6303618
*Bishop K, Ring SJ, Zoltai T, . 1985. Identification of asbestos and glass fibers in municipal sewage sludges. Bull Environ Contam Toxicol 34:301–308.3978268
*Bjornberg A. 1985. Glass fiber dermatitis. Am J Ind Med 8(4–5):395–400.4073038
*Bjornberg A, Lowhagen G-B. 1977. Patch testing with mineral wool (rockwool). Acta Derm Venereol (Stockh) 57(3):257–260.71833
*Bjornberg A, Lowhagen G-B, Tengberg J-E. 1979c. Does occupational exposure to glass-fibres increase the general skin reactivity to irritants? Contact Dermatitis 5(3):175–177.455965
*Bjornberg A, Lowhagen G, Tengberg JE. 1979b. Relationship between intensities of skin test reactions to glass-fibres and chemical irritants. Contact Dermatitis 5(3):171–174.556361
*Bjornberg A, Lowhagen G-S, Tengberg JE. 1979a. Skin reactivity in workers with and without itching from occupational exposure to glass fibers. Acta Derm Venereol (Stockh) 59(1):49–54.84467
*Boffetta P, Andersen A, Hansen J, . 1999. Cancer incidence among European man-made vitreous fiber production workers. Scand J Work Environ Health 25(3):222–226.10450772
*Boffetta P, Sali D, Kolstad H, . 1998. Mortality of short-term workers in two international cohorts. J Occup Environ Med 40(12):1120–1126.9871889
*Boffetta P, Saracci R, Andersen A, . 1992. Lung cancer mortality among workers in the European production of man-made mineral fibers- a Poisson regression analysis. Scand J Work Environ Health 18(5):279–286.1439653
*Boffetta P, Saracci R, Andersen A, . 1997. Cancer mortality among man-made vitreous fiber production workers. Epidemiology 8(3):259–268.9115020
Bolton RE. 1983. Fibres and fibrogenesis. Eur J Respir Dis 64:403–405.
Bolton RE, Davis JMG, Donaldson K, . 1982. Variations in the carcinogenicity of mineral fibres. Ann Occup Hyg 26(1–4):569–582.6295247
Borm PJA. 2002. Particle toxicology: From coal mining to nanotechnology. Inhal Toxicol 14:311–324.12028820
Botham SK, Holt PF. 1973. Comparison of effects of glass fibre and glass powder on guinea-pig lungs. Br J Ind Med 30:232–236.4124978
Bottin MC, Vigneron JC, Rousseau R, . 2003. Man-made mineral fiber hazardous properties assessment using transgenic rodents: Example of glass fiber testing. Inhal Toxicol 15:1017–1027.12928977
*Brackett KA, Clark PJ, Millette JR. 1992. Method for the analysis of asbestos fibers in water using MCE filters. Microscope 40:159–163.
*Breysse PN, Lees PSJ, Rooney BC. 1999. Comparison of NIOSH Method 7400 A and B counting rules for assessing synthetic vitreous fiber exposures. Am Ind Hyg Assoc J 60(4):526–532.
Breysse PN, Lees PSJ, Rooney BC, . 2001. End-user exposures to synthetic vitreous fibers: II. Fabrication and installation fabrication of commercial products. Appl Occup Environ Hyg 16:464–470.11318389
Brochard P, Pairon JC, Bignon J. 1994. The occupational physician’s point of view: The model of man-made vitreous fibers. Environ Health Perspect 102:31–36.
*Brody AR, Roe MW. 1983. Deposition pattern of inorganic particles at the alveolar level in the lungs of rats and mice. Am Rev Respir Dis 128(4):724–729.6625350
Brown RC. 1991. Carcinogenicity of the insulation wools: Reassessment of the IARC evaluation. Regul Toxicol Pharmacol 14:12–23.1947241
Brown RC. 2000. Influence of non-fibrous particles in the animal testing of refractory ceramic fibres. In: Rammlmair D, Mederer J, Pentinghaus H, eds. Applied mineralogy: In research, economy, technology, ecology and culture. Gottingen, Germany: Balkema Publishers.
*Brown DM, Beswick PH, Bell KS, . 2000. Depletion of glutathione and ascorbate in lung lining fluid by respirable fibres. Ann Occup Hyg 44(2):101–108.10717261
*Brown DM, Beswick PH, Donaldson K. 1999. Induction of nuclear translocation of NF-KB in epithelial cells by respirable mineral fibres. J Pathol 189:258–264.10547584
*Brown DM, Fisher C, Donaldson K. 1998. Free radical activity of synthetic vitreous fibers: Iron chelation inhibits hydroxyl radical generation by refractory ceramic fiber. J Toxicol Environ Health A 53(7):545–561.9561968
Brown GM, Cowie H, Davis JMG, . 1986. In vitro assays for detecting carcinogenic mineral fibres: a comparison of two assays and the role of fibre size. Carcinogenesis 7(12):1971–1974.3779893
*Brown RC, Chamberlain M, Davies R, . 1979a. In vitro biological effects of glass fibers. J Environ Pathol Toxicol 2(6):1369–1383.528847
*Brown RC, Chamberlain M, Skidmore JW. 1979b. In vitro effects of man-made mineral fibres. Ann Occup Hyg 22(2):175–179.533084
Brown RC, Hoskins JA, Miller K, . 1990. Pathogenetic mechanisms of asbestos and other mineral fibres. Mol Aspects Med 11(5):325–349.2203959
Brown RC, Poole A, Turver CJ. 1986. In vitro correlates of mineral dust toxicity. Food Chem Toxicol 24(6–7):535–538.3023214
*Brown RC, Sara EA, Hoskins JA, . 1992. The effects of heating and devitrification on the structure and biological activity of aluminosilicate refractory ceramic fibres. Ann Occup Hyg 36(2):115–129.1530229
*Brown RC, Sebastien P, Bellmann B, . 2000. Particle contamination in experimental fiber preparations. Inhal Toxicol 12(3):99–107.26368605
*Brüske-Hohlfeld I, Moehner M, Pohlabein H, . 2000. Occupational lung cancer risk for men in Germany: Results from a pooled case-control study. Am J Epidemiol 151(4):384–395.10695597
*Buchanich JM, Marsh GM, Youk AO. 2001. Historical cohort study of US man-made vitreous fiber production workers: V. Tobacco-smoking habits. J Occup Environ Med 43(9):793–802.11561362
Bunn WB, Bender JR, Hesterberg TW, . 1993. Recent studies of man-made vitreous fibers. J Occup Med 35(2):101–113.8166769
Bunn WB, Versen RA, Chase GR. 1991. An update on the health effects of man-made vitreous fibers and potential fiber exposures. Tappi J June 1991:136–143.
*Burge PS, Calvert IA, Trethowan WM, . 1995. Are the respiratory health effects found in manufacturers of ceramic fibres due to the dust rather than the exposure to fibres? Occup Environ Med 52:105–109.7757162
Camilucci L, Campopiano A, Casciardi S, . 2001. [Exposure to artificial mineral fibers in public buildings.] Med Lav 92(1):32–38. (Italian)11367825
*Carpenter RL, Wilson CL. 1999. The inhalation toxicity of glass fibers- a review of the scientific literature. Naval Health Research Center Detachment (Toxicology) (NHRC/TD).
*Carter CM, Axten CW, Byers CD, . 1999. Indoor airborne fiber levels of MMVF in residential and commercial buildings. Am Ind Hyg Assoc J 60(6):794–800.10635546
Carthew P, Edwards RE, Dorman BM, . 1995. Intrapleural administration of vitreous high duty ceramic fibres and heated devitrified ceramic fibres does not give rise to pleural mesothelioma in rats. Hum Exp Toxicol 14(8):657–661.7576833
Casciardi S, Camppoiano A, Fioravanti F, . 2003. [An example of size characterization of synthetic vitreous fibers.] Med Lav 94:542–555. (Italian)14768246
*Casey G. 1983. Sister-chromatid exchange and cell kinetics in CHO-K1 cells, human fibronblasts and lymphoblastoid cells exposed in vitro to asbestos and glass fibre. Mutat Res 116:369–377.6300672
*Chamberlain M, Tarmy EM. 1977. Asbestos and glass fibres in bacterial mutation tests. Mutat Res 43:159–164.194149
*Cheng RT, McDermott HJ, Gia GM, . 1992. Exposures to refractory ceramic fiber in refineries and chemical plants. Appl Occup Environ Hyg 7(6):361–367.
Cherrie J, Dodgson J. 1986. Past exposures to airbrone fibers and other potential risk factors in the European man-made mineral fiber production industry. Scand J Work Environ Health 12:26–33.3026036
Cherrie J, Dodgson J, Groat S, . 1987. Environmental surveys in the European man-made mineral fiber production. Scand J Work Environ Health 12:18–25.
*Chiazze L, Watkins DK, Fryar C. 1992. A case-control study of malignant and non-malignant respiratory disease among employees of a fiberglass manufacturing facility. Br J Ind Med 49:326–331.1599870
*Chiazze L, Watkins DK, Fryar C, . 1993. A case-control study of malignant and non-malignant respiratory disease among employees of a fiberglass manufacturing facility II. Exposure assessment. Br J Ind Med 50(8):717–725.8398858
*Chiazze L, Watkins DK, Fryar C. 1995. Adjustment for the confounding effect of cigarette smoking in an historical cohort mortality study of workers in a fiberglass manufacturing facility. J Occup Environ Med 37(6):744–748.7670922
*Chiazze L, Watkins DK, Fryar C. 1997. Historical cohort mortality study of a continuous filament fiberglass manufacturing plant. I. White men. J Occup Environ Med 39(5):432–441.9172088
*Chiazze L, Watkins DK, Fryar C, . 2002. Mortality from non-malignant respiratory disease in the fibreglass manufacturing industry. Occup Environ Med 59:369–372.12040110
*Christensen VR, Eastes W, Hamilton RD, . 1993. Fiber diameter distributions in typical MMVR wool insulation products. Am Ind Hyg Assoc J 54(5):232–238.
*Christensen VR, Jensen SL, Guldberg M, . 1994. Effect of chemical composition of man-made vitreous fibers on the rate of dissolution in vitro at different pHs. Environ Health Perspect 102:83–86.
*Churg A, Stevens B. 1995. Enhanced retention of asbestos fibers in the airways of human smokers. Am J Respir Crit Care Med 151:1409–1413.7735593
Churg A, Warnock ML, Bensch KG. 1978. Malignant mesothelioma arising after direct application of asbestos and fiber glass to the pericardium. Am Rev Respir Dis 118(2):419–424.697191
*Churg A, Wright JL, Hobson J, . 1992. Effects of cigarette smoke on the clearance of short asbestos fibres from the lung and a comparison with the clearance of long asbestos fibres. Int J Exp Path 73:287–297.1320393
*Churg A, Wright J, Gilks B, . 2000. Pathogenesis of fibrosis produced by asbestos and man-made mineral fibers: What makes a fiber fibrogenic? Inhal Toxicol 12:15–26.
Class P, Deghilage P, Brown RC. 2001. Dustiness of different high-temperature insulation wools and refractory ceramic fibres. Ann Occup Hyg 45(5):381–384.11418088
*Claude J, Frentzel-Beyme R. 1984. A mortality study of workers employed in a German rock wool factory. Scand J Work Environ Health 10:151–157.6474109
*Claude J, Frentzel-Beyme R. 1986. Mortality of workers in a German rock-wool factory-A second look with extended follow-up. Scand J Work Environ Health 12:53–60.3798055
*Clausen J, Netterstrom B, Wolff C. 1993. Lung function in insulation workers. Br J Ind Med 50:252–256.8457492
Cleland LG, Vernon-Roberts B, Smith K. 1984. Fibre glass induced synovitis. Ann Rheum Dis 43:530–534.6742919
*Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Clouter A, Houghton CE, Bowskill CA, . 1996. An in vitro/in vivo study into the short term effects of exposure to mineral fibres. Exp Toxicol Pathol 48:484–486.8954327
Clupper DC, Gough JE, Hall MM, . 2003. In vitro bioactivity of S520 glass fibers and initial assessment of osteoblast attachment. J Biomed Mater Res 67A:285–294.
*Colborn T, Clement C, eds. 1992. Chemically-induced alterations in sexual and functional development: The wildlife-human connection. In: Advances in modern environmental toxicology. Vol. XXI, Princeton, NJ: Princeton Scientific Publishing.
Collier CG, Morris KJ, Launder KA, . 1994. The behavior of glass fibers in the rat following intraperitoneal injection. Regul Toxicol Pharmacol 20:S89–S103.7724860
Collier CG, Morris KJ, Launder KA, . 1995. The durability and distribution of glass fibres in the rat following intra-peritoneal injection. Ann Occup Hyg 39(5):699–704.8526400
Corn M, Hammad Y, Whittier D, . 1976. Employee exposure in airborne fiber and total particulate matter in two mineral wool facilities. Environ Res 12:59–74.954709
*Cowie HA, Wild P, Beck J, . 2001. An epidemiological study of the respiratory health of workers in the European refractory ceramic fibre industry. Occup Environ Med 58:800–810.11706147
Cullen RT, Miller BG, Clark S, . 2002. Tumorigenicity of cellulose fibers injected into the rat peritoneal cavity. Inhal Toxicol 14:685–703.12122570
*Cullen RT, Searl A, Buchanan D, . 2000. Pathogenicity of a special-purpose glass microfiber (E Glass) relative to another glass microfiber and amosite asbestos. Inhal Toxicol 12(10):959–977.10989371
Cummings KM, Hastrup JL, Streck RJ, . 2000a. Correspondence Re: Cummings et al., consumer perception of risk associated with filters contaminated with glass fibers. Cancer Epidemiol Biomarkers Prev 10(4):417–418.
Cummings KM, Hastrup JL, Swedrock T, . 2000b. Consumer perception of risk associated with filters contaminated with glass fibers. Cancer Epidemiol Biomarkers Prev 9(9):977–979.11008918
*Dai YT, Yu CP. 1998. Alveolar deposition of fibers in rodents and humans. J Aerosol Med 11(4):247–258.10346667
Davies R. 1980. The effect of mineral fibres on macrophages. In: Wagner JC, Davis W, eds. Biological effects of mineral fibres. IARC Scientific Publication No. 30. Lyon, France, 419–425.
Davies L, Cherrie JW. 1992. Airborne fiber concentrations in a glass continuous filament factory. Ann Occup Hyg 36(6):609–627.
Davis JMG. 1972. The fibrogenic effects of mineral dusts injected into the pleural cavity of mice. Br J Exp Pathol 53:190–201.4338060
Davis JMG. 1986. A review of experimental evidence for the carcinogenicity of man-made vitreous fibers. Scand J Work Environ Health 12:12–17.3541171
Davis JA, Kalinowski MR. 1989. Development of LM/SEM/TEM methods for the quantitative analysis of airborne glass fiber levels. In: Russell PE, ed. 29th annual meeting of the Microbeam Analysis Society. San Francisco, CA: San Francisco Press, Inc., 427–428.
*Davis JMG, Addison RE, Bolton K, . 1984. The pathogenic effects of fibrous ceramic aluminum silicate glass administered to rats by inhalation and peritoneal injection. In: Biological effects of manmade mineral fibers. Proceedings of a WHO/IARC Conference, Vol. 2, Copenhagen, Denmark, April 20-22, 1982, 303–322.
*Davis JMG, Brown DM, Cullen RT, . 1996. A comparison if methods of determining and predicting the pathogenicity of mineral fibers. Inhal Toxicol 8(8):747–770.
*Davis JMG, Gylseth B, Morgan A. 1986. Assessment of mineral fibres from human lung tissue. Thorax 41:167–175.3520934
Dement JM. 1975. Environmental aspects of fibrous glass production and utilization. Environ Res 9:295–312.1157805
Denizeau F, Marion M, Chevalier G, . 1985. Absence of genotoxic effect of nonasbestos mineral fibers. Cell Biol Toxicol 1(2):23–32.2856044
Deren G. 1995. Refractory-ceramic-fiber furnace linings. Am Ceram Soc Bull 74(5):65–68.
DeVuyst P, Dumortier P, Swaen GMH, . 1995. Respiratory health effects of man-made vitreous (mineral) fibres. Eur Resp J 8(12):2149–2173.
Dodgson J, Ottery J, Cherrie JW, . 1980. Fibre concentrations and size distributions of airborne fibres in several European man-made mineral fibre plants. IARC Sci Publ 30:913–925.
Donaldson K. 1994. Biological activity of respirable industrial fibres treated to mimic residence in the lung. Toxicol Lett 72(1–3):299–305.8202944
Donaldson K. 2001. The toxicology of respirable industrial fibres: An overview. Toxicol Lett 123:11.11514101
Donaldson K, Tran CL. 2002. Inflammation caused by particles and fibers. Inhal Toxicol 14:5–27.12122558
Donaldson K, Brown DM, Miller BG, . 1995a. Bromo-deoxyuridine (BRDU) uptake in the lungs of rats inhaling amosite asbestos or vitreous fibers at equal airborne fibre concentrations. Exp Toxicol Pathol 47(2–3):207–211.7580110
*Donaldson K, Gilmour PS, Beswick PH. 1995c. Supercoiled plasmid DNA as a model target for assessing the generation of free radicals at the surface of fibres. Exp Toxicol Pathol 47(4):235–237.8855117
*Donaldson K, Hill IM, Beswick PH. 1995b. Superoxide anion release by alveolar macrophages exposed to respirable industrial fibres: modifying effect of fibre opsonisation. Exp Toxicol Pathol 47(4):229–231.8855115
*Dopp E, Schiffmann D. 1998. Analysis of chromosomal alteration induced by asbestos and ceramic fibers. Toxicol Lett 96:155–162.9820661
Dopp E, Nebe B, Hahnel C, . 1995. Mineral fibers induce apoptosis in Syrian hamster embryo fibroblasts. Pathobiology 63:213–221.8866793
*Dopp E, Schuler M, Schiffmann D, . 1997. Induction of micronucleai, hyperdiploidy and chromosomal breakage affecting the centri/pericentric regions of chromosomes 1 and 9 in human amniotic fluid cells after treatment with asbestos and ceramic fibers. Mutat Res 377:77–87.9219582
Dörger M, Allmeling A-M, Neuber A, . 1997. Interspecies comparison of rat and hamster alveolar macrophage antioxidative and oxidative capacity. Environ Health Perspect 105:1309–1312.9400743
*Dörger M, Munzing S, Allmeling A-M, . 2000. Comparison of the phagocytic response of rat and hamster alveolar macrophages to man-made vitreous fibers in vitro. Hum Exp Toxicol 19(11):635–640.11211242
*Dörger M, Munzing S, Allmeling AM, . 2001. Differential responses of rat alveolar and peritoneal macrophages to man-made vitreous fibers in vitro. Environ Res 85:207–214.11237509
*Driscoll KE. 1996. Effects of fibres on cell proliferation, cell activation and gene expression. IARC Sci Publ 140:73–96.
*Driscoll KE, Carter JM, Hassenbein DG, . 1997. Cytokines and particle-induced inflammatory cell recruitment. Environ Health Perspect 105(5):1159–1164.9400717
*Dufresne A, Perrault G, Yamato H, . 1999. Clearance of man made mineral fibres from the lungs of sheep. Occup Environ Med 56:684–690.10658548
*Dumortier P, Broucke I, DeVuyst P. 2001. Pseudoasbestos bodies and fibers in bronchoalveolar lavage of refractory ceramic fiber users. Am J Respir Crit Care Med 164(3):499–503.11500357
*Eastes W, Hadley JG. 1995. Dissolution of fibers inhaled by rats. Inhal Toxicol 7:179–196.
*Eastes W, Hadley JG. 1996. A mathematical model of fiber carcinogenicity and fibrosis in inhalation and intraperitoneal experiments in rats. Inhal Toxicol 8:323–343.
Eastes W, Hadley JG. 2001. Comment on “Long man-made fibers and lung cancer risk.” Regul Toxicol Pharmacol 33(2):268.11350208
*Eastes W, Morris KJ, Morgan A, . 1995. Dissolution of glass fibers in the rat lung following intratracheal instillation. Inhal Toxicol 7:197–213.
*Eastes W, Potter RM, Hadley JG. 2000. Estimating in vitro glass fiber dissolution rate from composition. Inhal Toxicol 12(4):269–280.10715628
*Ellenhorn MJ. 1997. Man-made mineral fibers (MMMF). In: Ellenhorn’s medical toxicology, 1515–1518.
Engholm G, Englund A, Fletcher AC, . 1987. Respiratory cancer incidence in Swedish construction workers exposed to man-made mineral fibres and asbestos. Ann Occup Hyg 31(48):663–675.3450233
*Engholm G, vonSchmalensee G. 1982. Bronchitis and exposure to man-made mineral fibres in nonsmoking construction workers. Eur J Respir Dis 118:73–78.
England EC, Carlton GN, Krevonick PL. 2000. The impact of ventilation systems on worker exposures during advanced composite material and fiberglass repair operations on military aircraft. Appl Occup Environ Hyg 15(5):391–396.10808259
*Enterline PE. 1990. Role of manmade mineral fibres in the causation of cancer. Br J Ind Med 47:145–145.2328220
*Enterline PE, Henderson V. 1975. The health of retired fibrous glass workers. Arch Environ Health 30:113–116.1115535
*Enterline PE, Marsh GM, Esmen NA. 1983. Respiratory disease among workers exposed to man-made mineral fibers. Am Rev Respir Dis 128(1):1–7.6870053
*Enterline PE, Marsh GM, Henderson V, . 1987. Mortality update of a cohort of U.S. man-made mineral fibre workers. Ann Occup Hyg 31(4B):625–656.3450231
*Environment Canada. 1993. Mineral fibres (man-made vitreous fibres). Priority Substances List Assessment Report.
*EPA. 1980. Man-made vitreous fibers and health. In: Proceedings of the National Workshop on Substitutes for Asbestos. U.S. Environmental Protection Agency. EPA560380001.
*EPA. 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA600890066A.
*EPA. 1992. ARARs fact sheet: Compliance with the clean air act and associated air quality requirements. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response. EPA9234222FS.
*EPA. 1995. Reportable Quantity Adjustments; final rule. Fed Regist 60(112):30925.
*EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R96012.
*Ernst P, Shapiro S, Dales RE, . 1987. Determinants of respiratory symptoms in insulation workers exposed to asbestos and synthetic mineral fibres. Br J Ind Med 44:90–95.3814550
*Esmen NA, Erdal S. 1990. Human occupational and nonoccupational exposure to fibers. Environ Health Perspect 88:277–286.2272324
*Esmen NA, Corn M, Hammad YY, . 1979a. Exposure of employees to man-made mineral fibers: Ceramic fiber production. Environ Res 19:265–278.499150
*Esmen N, Corn M, Hammad Y, . 1979b. Summary of measurements of employee exposure to airborne dust and fiber in sixteen facilities producing man-made mineral fibers. Am Ind Hyg Assoc J 40:108–117.495442
*Esmen NA, Hammad YY, Corn M, . 1978. Exposure to employees to man-made mineral fibers: Mineral wool production. Environ Res 15:262–277.352685
Estes W, Morris KJ, Morgan A, . 1995. Dissolution of glass fibers in the rat lung following intratracheal instillation. Inhal Toxicol 7(2):197–213.
*Eun HC, Lee HG, Paik NW. 1991. Patch test responses to rockwool of different diameters evaluated by cutaneous blood flow measurement. Contact Dermatitis 24(4):270–273.1868716
Everest Consulting Associates. 1996. Particulate-to-fiber ratios and fiber size distributions in the RCC maximum and tolerated dose (MTD) study and in the workplace. Presented to the U.S. Environmental Protection Agency. Prepared by Everest Consulting Associates, Cranbury, NJ.
*Everitt J, Bermudez E, Mangum J, . 1994. Acute pleural response of hamsters and rats to inhaled ceramic fibers. In: Dungworth DL, Mauderly JL, Oberdorster G, eds. Toxic and carcinogenic effects of solid particles in the respiratory tract. Washington DC: ILSI Press, 599–602.
*Everitt JI, Gelzleichter TR, Bermudez E, . 1997. Comparison of pleural responses of rats and hamsters to subchronic inhalation of refractory ceramic fibers. Environ Health Perspect 105:1209–121.9400725
Fallentin B, Kamstrup O. 1993. Simulation of past exposure in slag wool production. Ann Occup Hyg 37(4):419–433.8379619
Faux SP, Houghton CE, Hubbard A, . 2001. Increased expression of epidermal growth factor receptor in rat pleural mesothelial cells correlates with carcinogenicity of mineral fibres. Carcinogenesis 12(12):2275–2280.
Fayerweather WE, Bender JR, Hadley JG, . 1997. Quantitative risk assessment for a glass fiber insulation product. Regul Toxicol Pharmacol 25:103–120.9185887
Fayerweather WE, Eastes W, Cereghini F, . 2002. Quantitative risk assessment of durable glass fibers. Inhal Toxicol 14:553–568.12119068
*FEDRIP. 2002. Federal Research in Progress Database. National Technical Information Service, Springfield, VA.
*Feron VJ, Scherrenberg PM, Immel HR, . 1985. Pulmonary response of hamsters to fibrous glass: chronic effects of repeated intratracheal instillation with or without benzo[a]pyrene. Carcinogenesis 6:1495–1499.4042277
*Fisher AA. 1982. Fiberglass vs mineral wool (rockwool) dermatitis. Cutis 29:412–513.6212199
*Fisher BK, Warkentin JD. 1969. Fiber glass dermatitis. Arch Dermatol 99:717–719.5783083
*Fitzer E, Kleinholz R, Tiesler H, . 1988. Fibers, synthetic inorganics. In: Gerhartz W, Yamamoto YS, Elvers B, ., eds. Ullmann’s encyclopedia of industrial chemistry, 1–66.
Fogel P, Morsheidt C, Hanton D, . 1998. A formula for predicting the tumor incidence in intraperitoneal experiments with mineral fibers. Inhal Toxicol 10:875–893.
*Fomon SJ. 1966. Body composition of the infant: Part I: The male “reference infant.” In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
*Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
Forget G, Lacroix MJ, Brown RC, . 1986. Response of perifused alveolar macrophages to glass fibers: Effect of exposure duration and fiber length. Environ Res 39:124–135.3943503
*Forrester BG. 1997. Reactive airway dysfunction syndrome: Occurrence after exposure to a refractory ceramic fiber-phosphoric acid binder mixture. South Med J 90(4):447–450.9114842
Fowler DP, Balzer JL, Cooper WC. 1971. Exposure of insulation workers to airborne fibrous glass. Am Ind Hyg Assoc J 32(2):86–91.5572573
Foy JWD, Collier C, Swauger JE. 2003. A comparison of mathematical methods for the determination of in vitro dissolution constants for glass fibers. Inhal Toxicol 15:167–179.12528045
*Fraire AE, Greenberg SD, Spjut HJ, . 1994. Effect of fibrous glass on rat pleural mesothelium. Am J Respir Crit Care Med 1509:521–527.
*Friar JJ, Phillips AM. 1989. Exposure to man-made mineral fibres. In: Bignon J, Peto J, Saracci R, eds. Non-occupational exposure to mineral fibres. IARC Scientific Publication No. 90. Lyon, France, 299–303.
Friemann J, Muller KM, Pott F. 1990. Mesothelial proliferation due to asbestos and man-made fibres. Experimental studies on rat omentum. Pathol Res Pract 186(1):117–123.2156241
Fujoino A, Hori H, Higashi T, . 1995. In-vitro biological study to evaluate the toxic potentials of fibrous materials. Int J Occup Environ Health 1:21–28.9990153
Fustinoni S, Colosio C, Colombi A, . 1998. Albumin and hemoglobin adducts as biomarkers of exposure to styrene in fiberglass-reinforced-plastics workers. Int Arch Occup Environ Health 70:35–41.
*Gantner BA. 1986. Respiratory hazard from removal of ceramic fiber insulation from high temperature industrial furnaces. Am Ind Hyg Assoc J 47(9):530–534.3020958
*Gao H, Brick J, Ong S-h, . 1997. Selective hyperexpression of c-jun oncoprotein by glass fiber- and silica-transformed BALB/c-3T3 cells. Cancer Lett 112(1):65–69.9029170
*Gao HG, Whong W-Z, Jones WG, . 1995. Morphological transformation induced by glass fibers in BALB/c-3T3 cells. Teratog Carcinog Mutagen 15(2):63–71.8525469
Gardner IT, Uff JS. 1978. “Blue bodies” in a case of cryptogenic fibrosing alveolitis (desquamative type)- an ultra-structural study. Thorax 33:806–813.218319
Gardner MJ, Magnani C, Pannett B, . 1988. Lung cancer among glass fibre production workers: a case-control study. Br J Ind Med 45(9):613–618.3179236
*Gardner MJ, Winter PD, Pannett B, . 1986. Mortality study of workers in the man-made mineral fiber production industry in the UK. Scand J Work Environ Health 12:85–93.3798059
*Gaudichet A, Petit G, Billon-Galland MA, . 1989. Levels of atmospheric pollution by man-made fibres in buildings. In: Bignon J, Peto J, Saracci R, eds. Non-occupational exposure to mineral fibres. International Agency for Research on Cancer. IARC Scientific Publication No. 90. Lyon, France, 291–298.
Geiser M, Matter M, Maye I, . 2003. Influence of airspace geometry and surfactant on the retention of man-made vitreous fibers (MMVF 10a). Environ Health Perspect 111(7):895–901.12782489
*Gelzleichter TR, Bermudez E, Mangum JB, . 1996a. Pulmonary and pleural responses in Fischer 344 rats following short-term inhalation of a synthetic vitreous fiber. I. Quantitation of lung and pleural fiber burdens. Fundam Appl Toxicol 30(1):31–38.8812215
*Gelzleichter TR, Bermudez E, Mangum JB, . 1996b. Pulmonary and pleural responses in Fischer 344 rats following short-term inhalation of a synthetic vitreous fiber (II) Pathobiologic responses. Fundam Appl Toxicol 30(1):39–46.8812217
*Gelzleichter TR, Bermudez E, Mangum JB, . 1999. Comparison of pulmonary and pleural responses of rats and hamsters to inhaled refractory ceramic fibers. Toxicol Sci 49(1):93–101.10367346
*Gelzleichter TR, Mangum JB, Vermudez E, . 1996c. Pulmonary and pleural leukocytes from F344 rats produce elevated levels of fibronectin following inhalation of refractory ceramic fibers. Exp Toxicol Pathol 48(6):487–489.8954328
*Gibbs AR, Pooley FD, Griffiths DM, . 1996. A histopathological and mineralogical study of lung tissues from workers engaged in glass wool manufacture. In: Sixth international meeting on the toxicology of natural and man-made fibrous and non-fibrous particles: Lake Placid, NY Spetember 15-18, 1996. 157.
*Gilmour PS, Beswick PH, Brown DM, . 1995. Detection of surface free radical activity of respirable industrial fibres using supercoiled phiX174 plasmid DNA. Carcinogenesis 16(12):2973–2979.8603472
*Gilmour PS, Brown DM, Beswick PH, . 1997. Free radical activity of industrial fibers: Role of iron in oxidative stress and activation of transcription factors. Environ Health Perspect Suppl 105(5):1313–1317.9400744
*Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
Glass LR, Brown RC, Hoskins JA. 1995. Health effects of refractory ceramic fibres: scientific issues and policy considerations. Occup Environ Med 52(7):433–440.7670617
*GMIC. 2002. Overview of the U.S. glass industry. Glass Manufacturing Industry Council. http://www.gmic.org/. May 07, 2002.
Goldberg MS, Parent ME, Siemiatycki J. 2001. A case-control study of the relationship between the risk of colon cancer in men and exposures to occupational agents. Am J Ind Med 39:531–546.11385637
*Goldfrank LR. 1998. The pathophysiologic basis of medical toxicology. Part C. In: Goldfrank’s toxicologic emergencies, 482.
Goldsmith JR. 1986. Comparative epidemiology of men exposed to asbestos and man-made mineral fibers. Am J Ind Med 10(5–6):543–552.3812493
*Goldsmith JR, Goldsmith DF. 1993. Fiberglass or silica exposure and increased nephritis or ESRD (end-stage renal disease). Am J Ind Med 23:873–881.8392293
*Goldstein B, Rendall REG, Webster I. 1983. A comparison of the effects of exposure of baboons to crocidolite and fibrous-glass dusts. Environ Res 32:344–359.6315390
Gradon L, Podgorski A. 1992. Experimental study on fibrous particle deposition in the human nasal cast. J Aerosol Sci 23:S469–S472.
Greim H, Brinkmann B, Pohlenz-Michel C, . 2000. The necessity of developing new criteria for carcinogen classification of fibers by the MAK commission. Inhal Toxicol 12:419–425.26368644
*Greim H, Brom P, Schins R, . 2001. Toxicity of fibers and particles-report of the workshop held in Munich, Germany, 26-27 October 2000. Inhal Toxicol 13(9):737–754.11498804
Greim HA, Ziegler-Skylakakis K. 1997. Strategies for setting occupational exposure limits for particles. Environ Health Perspect 105:1357–1361.9400750
Griffis LC, Pickerell JA, Carpenter RL, . 1983. Deposition of crocidolite asbestos and glass microfibers inhaled by the beagle dog. Am Ind Hyg Assoc J 44(3):216–222.6303099
Grimm HG, Bernstein DM, Attia M, . 2002. Experience from a long-term carcinogenicity study with intraperitoneal injection of biosoluble synthetic mineral fibers. Inhal Toxicol 14:855–882.12122567
*Gross P. 1976. The biologic categorization of inhaled fiber glass dust. Arch Environ Health 31:101–107.769704
*Gross P. 1981. Consideration of the aerodynamic equivalent diameter of respirable mineral fibers. Am Ind Hyg Assoc J 42(6):449–452.
Gross P, Stanton MF. 1973. Tumors of the pleura induced with asbestos and fibrous glass. J Natl Cancer Inst 51(1):315–319.4720883
Gross P, Davis JMG, Harley RA, . 1973. Lymphatic transport of fibrous dust from the lungs. J Occup Med 15(3):186–189.4693160
Gross P, deTreville RTP, Cralley LJ. 1968. Pulmonary ferruginous bodies. Developed in response to filamentous dusts and a method of isolation and concentration. Arch Pathol 85:539–546.4172121
Gross P, deTreville RTP, Cralley LJ, . 1970. The pulmonary response to fibrous dusts of diverse compositions. Am Ind Hyg Assoc J 31:125–132.4316348
Gross P, Harley RA, Davis JMG, . 1974a. Mineral fiber content of human lungs. Am Ind Hyg Assoc J 35(3):148–151.4821303
Gross P, Harley RA, Swinburne LM, . 1974b. Ingested mineral fibers. Do they penetrate tissue or cause cancer? Arch Environ Health 29:341–347.4429402
Gross P, Kaschak M, Tolker EB, . 1970. The pulmonary reaction to high concentrations of fibrous glass dust. Arch Environ Health 20:696–704.5443343
Gross P, Theodos PA, Murphy RLH. 1976. The pulmonary response to fiberglass dust- Report to the Committee on Environmental Health. American College of Chest Physicians. Chest 69(2):216–219.765070
Gross P, Tuma J, DeTrebille RTP. 1971. Lungs of workers exposed to fiber glass. Arch Environ Health 23:67–76.4103314
Gross P, Westrick ML, Schrenk HH, . 1956. The effects of a synthetic ceramic fiber dust upon the lungs of rats. AMA Arch Ind Health 13(2):161–166.13282516
Guldberg M, Jensen SL, Knudsen T, . 2002. High-alumina low-silica HT stone wool fibers: A chemical compositional range with high biosolubility. Regul Toxicol Pharmacol 35:217–226.12052006
Gulumian M, Van Wyk JA. 1987. Hydroxyl radical production in the presence of fibres by a fenton-type reaction. Chem Biol Interact 62:89–97.3034439
*Gustavsson P, Plato N, Axelson O, . 1992. Lung cancer risk among workers exposed to man-made mineral fibers (MMMF) in the Swedish prefabricated house industry. Am J Ind Med 21(6):825–834.1621690
Gutknecht MHG. 1999. [Results of workplace exposure measurements of refractory ceramic fibers.] Geharstoffe Reinhalt Luft 59(5):171–177. (German)
*Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
*Hall GS, Rice CH, Lockey JE, . 1997. A comparison of exposures to refractory ceramic fibres over multiple work shifts. Ann Occup Hyg 41(5):555–560.9332159
Hamilton RD, Miiler WC, Christensen DR, . 1994. Characterization of exposure and dose of man made vitreous fiber in experimental studies. Environ Health Perspect 102:109–112.
Hammad YY, Attieh B. 1989. Pulmonary deposition of MMMF. J Aerosol Sci 20(8):1329–1332.
Hammad YY, Atieh B. 1994. Long-term clearance of ceramic fibers from guinea pig lungs. In: Dungworth DL, Mauderly JL, Oberdorster G, eds. Toxic and carcinogenic effects of solid particles in the respiratory tract. Washington, DC: ILSI Press, 477–449.
Hammad YY, Atieh B. 1995. Long-term clearance of ceramic fibers from guinea-pig lungs. Exp Toxicol Pathol 47:192–194.7580107
Hammad Y, Diem J, Craighead J, . 1982. Deposition of inhaled man made mineral fibres in the lungs of rats. Ann Occup Hyg 26(1):179–187.7181264
Hansen ES. 2002. Comments on a nested case-control study of lung cancer among European rock and slag wool production workers. Int J Occup Environ Health 8:281–283.12358085
*Hansen E, Rasmussen F, Hardt F, . 1999. Lung function and respiratory health of long-term fiber-exposed stonewool factory workers. Am J Respir Crit Care Med 160(2):466–472.10430715
Hansen J, Boffetta P, Anderson A, . 1997. Comparison of information on occupation and lifestyle habits obtained from European man-made vitreous fibre production workers and their relatives. Int J Epidemiol 26(5):1009–1016.9363522
Hanton DY, Furtak H, Grimm HG. 1998. Preparation and handling conditions of MMVF for in-vivo experiments. Aerosol Sci Technol 29(5):449–456.
*Haratake J, Yamato H, Hori H, . 1995. Histopathologic examinations of rats treated by chronic inhalation exposures to glass fibers. Inhal Toxicol 7:343–352.
*Hart GA, Kathman LM, Hesterberg TW. 1994. In vitro cytotoxicity of asbestos and man-made vitreous fibers: Roles of fiber length, diameter and composition. Carcinogenesis 15(5):971–977.8200103
*Hart GA, Newman MM, Bunn WB, . 1992. Cytotoxicity of refractory ceramic fibres to Chinese hamster ovary cells in culture. Toxicol in Vitro 6(4):317–326.20732128
Hashish AH, Fleming JS, Conway J, . 1998. Lung deposition of particles by airway generation in healthy subjects: three-dimensional radionuclide imaging and numerical model prediction. J Aerosol Sci 29(1/2):205–215.
*HazDat. 2004. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA. http://www.atsdr.cdc.gov/hazdat.html. January 12, 2004.
*Hecht E. 1989. Optics. Second edition. Spatz B, ed. Reading, MA: Addison-Wesley Publishing Company, Inc., 191–192.
Heise H, Mattheus A. 1971. [Skin reactions to insulators: I. Epicutaneous testing of mineral fibers.] Dermatol Monatsschr 157(1):52–61. (German)5096966
Heise H, Mattheus A. 1971. [Skin reactions to insulators: II. Relationships to frequent allergens.] Dermatol Monatsschr 157(1):62–67. (German)5096967
*Heisel EB, Hunt FE. 1968. Further studies in cutaneous reactions to glass fibers. Arch Environ Health 17:705–711.5687266
*Hesterberg TW, Barrett JC. 1984. Dependence of asbestos-and mineral dust-induced transformation of mammalian cells in culture on fiber dimension. Cancer Res 44:2170–2180.6324999
Hesterberg TW, Chase GR. 1995. Commentary on “Fibrous glass and lung cancer”. Letter to the editor. Am J Ind Med 30:111–112.
Hesterberg TW, Hart GA. 1994. A comparison of human exposures to fiberglass with those used in a recent rat chronic inhalation study. Regul Toxicol Pharmacol 20:S35–S46.7724854
*Hesterberg TW, Hart GA. 1998. Health and safety aspects of fiber glass. Nonwoven Conference and Trade Fair, St. Petersburg, FL, March 9-11, 1998. Atlanta, GA: TAPPI Press, 269–288.
*Hesterberg TW, Hart GA. 2000. Lung biopersistence and in vitro dissolution rate predict the pathogenic potential of synthetic vitreous fibers. Inhal Toxicol 12:91–97.
*Hesterberg TW, Hart GA. 2001. Synthetic vitreous fibers: A review of toxicology research and its impact on hazard classification. Crit Rev Toxicol 31(1):1–53.11215691
Hesterberg TW, Axten C, McConnell EE, . 1997. Chronic inhalation study of fiber glass and amosite asbestos in hamsters: Twelve-month preliminary results. Environ Health Perspect Suppl 105(5):1223–1229.9400728
*Hesterberg TW, Axten C, McConnell EE, . 1999. Studies on the inhalation toxicology of two fiberglasses and amosite asbestos in the Syrian golden hamster. Part I. Results of a subchronic study and dose selection for a chronic study. Inhal Toxicol 11(9):747–784.10477658
Hesterberg TW, Butterick CJ, Oshimura M. 1986. Role of phagocytosis in Syrian hamster cell transformation and cytogenetic effects induced by asbestos and short and long glass fibers. Cancer Res 46(11):5795–5802.3756923
*Hesterberg TW, Chase G, Axten C, . 1998a. Biopersistence of synthetic vitreous fibers and amosite asbestos in the rat lung following inhalation. Toxicol Appl Pharmacol 151:262–275.9707503
*Hesterberg TW, Chase G, Axten C, . 1999. Erratum: Biopersistence of synthetic vitreous fibers and amosite asbestos in the rat lung following inhalation. Toxicol Appl Pharmacol 155:292.10079216
*Hesterberg TW, Hart GA, Bunn WB. 1993a. In vitro toxicology of fibers: mechanistic studies and possible use for screening assays. In: Warheit DB, ed. Fiber toxicology. Chapter 7. San Diego, CA: Academic Press, Inc., 139–170.
*Hesterberg TW, Hart GA, Chevalier J, . 1998b. The importance of fiber biopersistence and lung dose in determining the chronic inhalation effects of X607, RCF1, and chrysotile asbestos in rats. Toxicol Appl Pharmacol 153:68–82.9875301
Hesterberg TW, Hart GA, Miiller WC, . 2002. Use of short-term assays to evaluate the potential toxicity of two new biosoluble glasswool fibers. Inhal Toxicol 14:217–246.12028814
Hesterberg TW, Miiller WC, Anderson R. 1993b. Chronic inhalation studies of man-made vitreous fibers. Proceedings of the 22nd DOE/NRC Nuclear Air Cleaning Conference 1992. Vol 1:191–204.
Hesterberg TW, Miiller WC, Mast R, . 1994. Relationship between lung biopersistence and biological effects of man-made vitreous fibers after chronic inhalation in rats. Environ Health Perspect 102:133–137.
*Hesterberg TW, Miiller WC, McConnell EE, . 1993c. Chronic inhalation toxicity of size-separated glass fibers in Fischer 344 rats. Fundam Appl Toxicol 20:464–476.8390950
*Hesterberg TW, Miiller WC, McConnell EE, . 1994. Chronic inhalation toxicity of man-made vitreous fibers: Relationship to lung burden and lung retention. In: Dungworth DL, Mauderly JL, Oberdorster G, eds. Toxic and carcinogenic effects of solid particles in the respiratory tract. Washington, DC: ILSI Press., 455–459.
*Hesterberg TW, Miiller WC, Musselman RP, . 1996. Biopersistence of man-made vitreous fibers and crocidolite asbestos in the rat lung following inhalation. Fundam Appl Toxicol 29:267–279.
*Hesterberg TW, Oshimura M, Barrett JC. 1985. In: Beck EG, Bignon J, eds. In vitro effects of mineral dusts. Third International Workshop. Berlin: Springer-Verlag, 185–196.
Hill IM, Beswick PH, Donaldson K. 1996. Enhancement of the macrophage oxidative burst by immunoglobulin coating of respirable fibers: Fiber-specific differences between asbestos and man-made fibers. Exp Lung Res 22(2):133–148.8706632
*Hill JW, Whitehead WS, Cameron JD, . 1973. Glass fibres: absence of pulmonary hazard in production workers. Br J Ind Med 30:174–179.4703089
Hinnen U, Elsner P, Barraud M, . 1997. Foreign body granuloma of the penis caused by occupational glass fibre exposure. Genitourin Med 73:577–578.9582491
Hippeli S, Dornisch K, Kaiser S, . 1997. Biological durability and oxidative potential of a stonewool mineral fibre compared to crocidolite asbestos fibers. Arch Toxicol 71(8):532–535.9248633
*Hirvonen A. 1997. Combinations of susceptible genotypes and individual responses to toxicants. Environ Health Perspect 105(suppl 4):755–757.9255557
Hirvonen A, Mattson K, Karjaiainen T, . 1999. Simian virus 40 (SV40)-like DNA sequences not detectable in Finnish mesothelioma patients not exposed to SV40-contaminated polio vaccines. Mol Carcinog 26:93–99.10506753
*Hirvonen A, Saarikoski ST, Linnainmaa K, . 1996. Gluthione S-transferase and N-acetyltransferase genotypes and asbestos-associated pulmonary disorders. J Natl Cancer Inst 88(24):1853–1856.8961976
Hoch-Ligetti C, Sass B, Sobel HJ, . 1983. Endocardial tumors in rats exposed to durable fibrous materials. J Natl Cancer Inst 71(5):1067–1071.6580483
*Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
*Hohr D. 1985. [Investigations by transmission electron microscopy of fibrous particles in ambient air.] Staub Reinhalt Luft 45:171–174. (German)
Holmes A, Morgan A, Davison W. 1983. Formation of pseudo-asbestos bodies on sized glass fibres in the hamster lung. Ann Occup Hyg 27(3):301–313.6638764
Hori H, Ishimatsu S, Oyabu T, . 1999. A clearance model of inhaled man-made fibers in rat lungs. Ind Health 37(1):103–107.10052307
Horowitz LD. 1978. NIOSH Criteria Document on fibrous glass. J Occup Med 20(11):718, 720.712438
*Horvath HP. 1995. Health effects of man-made mineral fibers. Cleve Clin J Med 62(1):8–19.7859409
Hoskins JA, Brown RC. 1994. Contamination of the air with mineral fibers following the explosive destruction of buildings and fire. Drug Metab Rev 26(4):663–673.7875060
Howden PJ, Faux SP. 1996a. Fibre-induced lipid peroxidation leads to DNA adduct formation in Salmonella typhimurium TA104 and rat lung fibroblasts. Carcinogenesis 17(3):413–419.8631125
Howden PJ, Faux SP. 1996b. Glutathione modulates the formation of 8-hydroxdeoxyguanosine in isolated DNA and mutagenicity in Salmonella typhimurium TA 100 induced by mineral fibres. Carcinogenesis 17(10):2275–2277.8895501
Huang JQ, Ji CM. 1994. A survey of the health effect of continuous filament glass fibre on long-term exposed workers. Ann Occup Hyg 38:763–768.
Huff J. 2002. IARC monographs, industrial influence, and upgrading, downgrading, and under-grading chemicals. Int J Occup Environ Health 8:249–270.12358081
*Hughes JM, Jones RN, Glindmeyer HW, . 1993. Follow up study of workers exposed to man made mineral fibres. Br J Ind Med 50:658–667.8343428
*Hunting KL, Welch LS. 1993. Occupational exposure to dust and lung disease among sheet metal workers. Br J Ind Med 50(5):432–442.8507596
IARC. 1987. Asbestos. IARC monographs programme on the evaluation of carcinogenic risks to humans. International Agency for Research on Cancer. http://193.51.164.11/htdocs/Monographs/Suppl7/Asbestos.html. May 07, 2002.
*IARC. 1988. IARC monographs of the evaluation of carcinogenic risks to human. International Agency for Research on Cancer. Lyon, France: World Health Organization. IARC Sci Publ 43:39–171.
*IARC. 2001. Man-made mineral fibres. IARC monographs programme on the evaluation of carcinogenic risks to humans. International Agency for Research on Cancer. http://193.51.164.11/htdocs/Monographs/Vol43/43-01.htm. May 07, 2002.
*IARC. 2002. Man-made mineral fibres. IARC monographs programme on the evaluation of carcinogenic risks to humans. International Agency for Research on Cancer. http://193.51.164.11/htdocs/monographs/vol81/81.html. Feburary 02, 2004.
*IARC Expert Panel. 1996. Congress report. In: Kane AB, Boffetta P, Saracci R, ., eds. Mechanisms of fibre carcinogenesis. International Agency for Research on Cancer. Scientific Publications No. 140, 1–9.
Infante PF, Schuman LD, Dement J, . 1994a. Fibrous glass and cancer. Am J Ind Med 26:559–584.7810554
Infante PF, Schuman LD, Dement J, . 1994b. Fibrous glass and cancer: Commentary. Am J Ind Med 26:559–584.7810554
Infante PF, Schuman LD, Huff J. 1996. Fibrous glass insulation and cancer: Response and rebuttal. Am J Ind Med 30:113–120.16374937
*ILO. 1989. International Labour Office. Guidelines for the use of the ILO international classification of radiographs of pneumoconiosis, revised edition. Geneva, Switzerland: ILO Occupational Safety and Health Series. No. 22.
ILSI. 2000. The relevance of the rat lung response to particle overload for human risk assessment: A workshop concensus report. ILSI Risk Science Institute Workshop. International Life Sciences Institute. Inhal Toxicol 12:1–17.
*IRIS. 2004. Integrated Risk Information System. http://www.epa.gov/iris. January 08, 2004.
Ishihara Y. 2001. In vitro studies on biological effects of fibrous minerals. Ind Health 39:94–105.11341563
Ishimatsu S, Oyabu T, Hori H, . 1999. A new digestion method for recovery of MMMFs from lungs. Ind Health 37(3):307–312.10441902
Iwata T, Yano E. 2003. Reactive oxygen metabolite production induced by asbestos and glass fibers: Effect of fiber milling. Ind Health 41:32–38.12674551
*Jacob TR, Hadley JG, Bender JR, . 1992. Airborne glass fiber concentrations during installation of residential insulation. Am Ind Hyg Assoc J 53(8):519–523.
*Jacob TR, Hadley JG, Bender JR, . 1993. Airborne glass fiber concentrations during manufacturing operations involving glass wool insulation. Am Ind Hyg Assoc J 54(6):320–326.
Jacobsen M. 1983. Do we know enough from epidemiology to prevent asbestosis? Eur J Respir Dis 64:407–408.
*Jaffrey TSAM. 1990. Levels of airborne man-made mineral fibres in UK dwellings. I. Fibre levels during and after installation of insulation. Atmos Environ 24A(1):133–141.
Janssen YMV, Borm PJA, Marsh JP, . 1994b. The role of active oxygen species in lung toxicity induced by mineral fibers and particulates. Adv Environ Sci Technol 28:445–457.
*Janssen YMW, Heintz NH, Marsh JP, . 1994a. Induction of c-fos and c-jun proto-oncogenes in target cells of the lung and pleura by carcinogenic fibers. Am J Respir Cell Mol Biol 11:522–530.7946382
*Jarvholm B, Jarliden A-K, Lilja B-G, . 1995. Occurrence of pleural plaques in workers with exposure to mineral wool. Int Arch Occup Environ Health 67(5):343–346.8543383
Jaurand M-C. 1997. Mechanisms of fiber-induced genotoxicity. Environ Health Perspect Suppl 105(5):1073–1084.9400703
Jaurand MC, Magne L, Bignon J, . 1980. Effects of well-defined fibres on red blood cells and alveolar macrophages. In: Wagner JC, Davis W, eds. Biological effects of mineral fibres. IARC Scientific Publication No. 30. Lyon, France.
*Jeffress CN. 1999. Written communication (May 18, 1999) to Kenneth Mentzer, Executive Vice President, OSHA regarding expression of support for the “Health and Safety Partnership Program” to help protect employees involved in manufacturing, installing, and removing products containing synthetic vitreous fibers.
*Jensen CG, Watson M. 1999. Inhibition of cytokinesis by asbestos and synthetic fibres. Cell Biol Int 23(12):829–840.10772757
*Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
Johnson NF. 1993. The limitations of inhalation, intratracheal, and intracoelomic routes of administration for identifying hazardous fibrous materials. In: Warheit DB, ed. Fiber toxicology. Chapter 3. San Diego, CA: Academic Press, Inc., 43–72.
Johnson NF. 1994. An overview of animal models for assessing synthetic vitreous fibers (SVFs) safety. Regul Toxicol Pharmacol 20:S7–S21.7724858
Johnson NF. 1994. Phasgosomal pH and glass fiber dissolution in cultured nasal epithelial cells and alveolar macrophages: A preliminary study. Environ Health Perspect 102:97–102.
Johnson NF, Hahn FF. 1996. Induction of mesothelioma after intrapleural inoculation of F344 rats with silicon carbide whiskers or continuous ceramic filaments. Occup Environ Med 53(12):813–816.8994400
*Johnson NF, Jaramillo RJ. 1997. p53, Cip 1, and Gadd 153 expression following treatment of A549 cells with natural and man-made vitreous fibers. Environ Health Perspect 105:1143–1145.9400714
*Johnson NF, Wagner JC. 1980. A study by electron microscopy of the effects of chrysotile and man-made mineral fibres on rat lungs. In: Wagner JC, Davis W, eds. Biological effects of mineral fibers. IARC Sci Publ 30:293–303.
*Johnson DL, Healey JJ, Ayer EA, . 1969. Exposure to fibers in the manufacture of fibrous glass. Am Ind Hyg Assoc J 30:545–550.5369267
Johnson NF, Hoover MD, Thomassen DG, . 1992. In vitro activity of silicon carbide whiskers in comparison to other industrial fibers using four cell culture systems. Am J Ind Med 21(6):807–823.1320327
Jolanki R, Makinen I, Suuronen K, . 2002. Occupational irritant contact dermatitis from synthetic mineral fibres according to Finnish statistics. Contact Dermatitis 47:329–333.12581277
*Jones AD. 1993. Respirable industrial fibres: Deposition, clearance and dissolution in animal models. Ann Occup Hyg 37(2):211–226.8317856
Julier F, Tiesler H, Zindler G. 1993. [Measurement of fibrous dust concentrations when handling mineral-wool insulations on industrial building sites.] Staub Reinhalt Luft 53(6):245–250. (German)
*Kamstrup O, Davis JMG, Ellehauge A, . 1998. The biopersistence and pathogenicity of man-made vitreous fibres after short- and long-term inhalation. Ann Occup Hyg 42(3):191–199.9684559
*Kamstrup O, Ellehauge A, Chevalier J, . 2001. Chronic inhalation studies of two types of stone wool fibers in rats. Inhal Toxicol 13(7):603–621.11452357
Kamstrup O, Ellehauge A, Collier CG, . 2002. Carcinogenicity studies after intraperitoneal injection of two types of stone wool fibres in rats. Ann Occup Hyg 46:135–142.12074022
*Kane AB. 1996. Mechanisms of mineral fibre carcinogenesis. In: Kane AB, Bofetta P, Saracci R, ., eds. Mechanisms of fibre carcinogenesis. International Agency for Research on Cancer, 11–34.
Keegan TE, Simmons JE, Pegram RA. 1998. NOAEL and LOAEL determinations of acute hepatotoxicity for chloroform and bromodichloromethane delivered in an aqueous vehicle to F344 rats. J Toxicol Environ Health A 55(1):65–75.9747604
Kelly JT, Kimbell JS, Asgharian B. 2001. Particle deposition in a rat nasal mold. CIIT Activities. Research Triangle Park, NC: CIIT Centers for Health Professionals, 1–6.
*Kelsey KT, Nelson HN, Wiencke JK, . 1997. The glutathione S-transferase Θ and µ deletion polymorphisms in asbestosis. Am J Ind Med 31:274–279.9055949
*Kiec-Swierczynska M, Szymczk W. 1995. The effect of the working environment on occupational skin disease development in workers processing rockwool. Int J Occup Med Environ Health 8(1):17–22.7640906
*Kiec-Swierczynska M, Wojtczak J. 2000. Occupational ceramic fibres dermatitis in Poland. Occup Med 50(5):337–342.
Kilburn KH. 1993. Pulmonary effects of exposure to fine fiberglass: irregular opacities and small airways obstruction. Reply to comments. Br J Ind Med 50(4):383–384.
*Kilburn KH, Warshaw RH. 1992. Difficulties of attribution of effect in workers exposed to fiberglass and asbestos. Am Ind Hyg Assoc J 20(6):745–751.
*Kilburn KH, Powers D, Warshaw RH. 1992. Pulmonary effects of exposure to fine fiberglass: irregular opacities and small airways obstruction. Br J Ind Med 49:714–720.1419860
Kim J-H, Chang H-S, Kim K-Y, . 1999. Environmental measurements of total dust and fiber concentration in manufacturer and user of man-made mineral fibers. Ind Health 37(3):322–328.10441904
Kim K-A, Lee WK, Kim JK, . 2001. Mechanism of refractory ceramic fiber- and rock wool-induced cytotoxicity in alveolar macrophages. Int Arch Occup Environ Health 74(1):9–15.11196086
*Kjaerheim K, Boffetta P, Hansen J, . 2002. Lung cancer among rock and slag wool production workers. Epidemiology 13:445–453.12094100
Klingholz R. 1977. Technology and production of man-made mineral fibres. Ann Occup Hyg 20:153–159.931274
*Knudsen T, Guldberg M, Christensen VR, . 1996. New type of stone wool (HT fibres) with a high dissolution rate at pH=4.5. Glastech Ber 69(10):331–337.
Koenig AR, Axten CW. 1995. Exposures to airborne fiber and free crystalline silica during installation of commercial and industrial mineral wool products. Am Ind Hyg Assoc J 56(10):1016–1022.
*Koh D, Khoo NY. 1995. Environmental glass fibre counts and skin symptoms. Contact Dermatitis 32(3):185.7774205
*Koh D, Aw TC, Foulds IS. 1992. Fiberglass dermatitis from printed circuit boards. Am J Ind Med 21:193–198.1531570
*Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29:4430–4433.2350547
Konzen J. 1975. Observations on fibrous glass in relation to health. In: Zenz C, ed. Occupational medicine. Principles and practical applications. Chapter 13. Chicago, IL: YearBook Medical Publishers, Inc., 231–238.
Konzen JL. 1980. Man-made vitreous fibers and health. Proceedings National Workshop on Substitutes for Asbestos. EPA560380001.
Konzen JL. 1994. Comment on: Occupational exposure to dust and lung disease among sheet metal workers. Br J Ind Med 50(5):432–442.
*Koshi K, Kohyama N, Myojo T, . 1991. Cell toxicity hemolytic action and clastogenic activity of asbestos and its substitutes. Ind Health 29(2):37–56.1832142
Krantz S. 1988. Exposure to man-made mineral fibers at ten production plants in Sweden. Scand J Work Environ Health 14:49–51.
*Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
*Krishnan K, Andersen ME, Clewell HJ III, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kudo Y, Watanabe M, Okada M, . 2003. Comparative cytotoxicity study of rock wool and chrysotile by cell magnetometric evaluation. Inhal Toxicol 15:1275–1295.14569493
Lafuma J, Morin M, Poncy JL, . 1980. Mesothelioma induced by intrapleural injection of different types of fibres in rats; synergistic effect of other carcinogens. In: Wagner JC, Davis W, eds. Biological effects of mineral fibres. IARC Sci Publ 30:311–320.
Lambre C, Schorsch F, Blanchard O, . 1998. An evaluation of the carcinogenic potential of five man-made vitreous fibers using the intraperitoneal test. Inhal Toxicol 10(11):995–1021.
Law BD, Bunn WB, Hesterberg TW. 1990. Solubility of polymeric organic fibers and manmade vitreous fibers in gambles solution. Inhal Toxicol 2(4):321–339.
Law BD, Bunn WB, Hesterberg TW. 1991. Dissolution of natural mineral and man-made vitreous fibers in Karnovsky’s and formalin fixatives. Inhal Toxicol 3(3):309–321.
*Lea CS, Hertz-Picciotto I, Andersen A, . 1999. Gender differences in the healthy worker effect among synthetic vitreous fiber workers. Am J Epidemiol 150(10):1099–1106.10568626
Leadbetter MR, Corn M. 1972. Particle size distribution of rat lung residues after exposure to fiberglass dust clouds. Am Ind Hyg Assoc J 33(8):511–522.4573178
*Leanderson P, Tagesson C. 1989. Cigarette smoke potentiates the DNA-damaging effect of manmade mineral fibers. Am J Ind Med 16(6):697–706.2556915
*Leanderson P, Soderkvist P, Tagesson C, . 1988. Formation of 8-hydroxydeoxyguanosine by asbestos and man made mineral fibres. Br J Ind Med 45:309–311.2837271
*Leanderson P, Soderkvist P, Tagesson C. 1989. Hydroxyl radical mediated DNA base modification by manmade mineral fibres. Br J Ind Med 46:435–438.2765416
*LeBouffant L, Daniel H, Henin JP, . 1987. Experimental study on long-term effects of inhaled MMMF on the lungs of rats. Ann Occup Hyg 31(48):765–790.3450235
*Lee J-M, Hennekens CH, Trichopoulos D, . 1995. Man-made vitreous fibers and risk of respiratory system cancer: A review of the epidemiologic evidence. J Occup Environ Med 37(6):725–738.7670920
Lee KP, Barras CE, Griffith FD. 1979. Pulmonary response to glass fiber by inhalation exposure. Lab Invest 40(2):123–133.372672
*Lee KP, Barras CE, Griffith FD, . 1981b. Comparative pulmonary responses to inhaled inorganic fibers with asbestos and fiberglass. Environ Res 24:167–191.6260477
*Lee KP, Barras CE, Griffith FD, . 1981a. Pulmonary response and transmigration of inorganic fibers by inhalation exposure. Am J Pathol 102(3):314–323.7212016
*Lee WJ, Baris D, Jarvholm B, . 2003. Multiple myeloma and diesel and other occupational exposures in Swedish construction workers. Int J Cancer 107:134–138.12925968
*Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Lees PSJ, Breysse PN, McArthur BR, . 1993. End user exposures to man-made vitreous fibers: I. Installation of residential insulation products. Appl Occup Environ Hyg 8(12):1022–1030.
*Leikauf GD, Fink SP, Miller M, . 1995. Refractory ceramic fibers activate alveolar macrophage eicosanoid and cytokine release. J Appl Physiol 78(1):164–171.7713806
Lemaire I, Dionne PG, Nadeau D, . 1989. Rat lung reactivity to natural and man-made fibrous silicates following short-term exposure. Environ Res 48:193–210.2538326
*Lemasters G, Lockey J, Levin L, . 1998. An industry-wide pulmonary study of men and women manufacturing refractory ceramic fibers. Am J Epidemiol 148(9):910–919.9801022
Lemasters G, Lockey J, Levin L, . 2001. A longitudinal study of chest radiographic changes and mortality of workers in the refractory ceramic fiber industry. Am J Epidemiol 153(11):S264.
*Lemasters G, Lockey J, Rice C, . 1994. Radiographic changes among workers manufacturing refractory ceramic fibre and products. Ann Occup Hyg 38:745–751.
*Lemasters G, Lockey J, Yiin JH, . 2003. Mortality of workers occupationally exposed to refractory ceramic fibers. J Occup Environ Med 45:440–450.12708148
Lemen RA. 2001. Fiberglass. In: Bingham E, Cohrssen B, Powell CH, eds. Patty’s toxicology. John Wiley & Sons, 575–582.
Lentz TJ, Rice CH, Lockey JE. 1999. Potential significance of airborne fiber dimensions measured in the US refractory ceramic fiber manufacturing industry. Am J Ind Med 36(2):286–298.10398937
*Lentz TJ, Rice CH, Succop PA, . 2003. Pulmonary deposition modeling with airborne fiber exposure data: A study of workers manufacturing refractory ceramic fibers. Appl Occup Environ Hyg 18:278–288.12637238
*Leung H-W. 1993. Physiologically-based pharmacokinetic modeling. In: Ballentine B, Marro T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Lindgren F, Sjosstrom M, Berglind R, . 1996. Modeling of the biological activity for a set of ceramic fibre materials: A QSAR study. SAR QSAR Environ Res 5:299–310.9104784
*Lippmann M. 1990. Effects of fiber characteristics on lung deposition, retention, and disease. Environ Health Perspect 88:311–317.2272328
*Lippmann M. 1994. Deposition and retention of inhaled fibres: effects on incidence of lung cancer and mesothelioma. Occup Environ Med 51:793–798.7849861
*Livingston, AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
Lockey JE. 1996. Man-made fibers and nonasbestos fibrous silicates. In: Harber P, Scheneker MB, Balmes JR, eds. Occupational and respiratory disease. Chapter 21. Mosby-Year Book, Inc., 330–344.
*Lockey JE, Lemasters GK, Levin L, . 2002. A longitudinal study of chest radiographic changes of workers in the refractory ceramic fiber industry. Chest 121:2044–2051.12065376
*Lockey J, Lemasters G, Rice C, . 1996. Refractory ceramic fiber exposure and pleural plaques. Am J Respir Crit Care Med 154(5):1405–1410.8912756
*Lockey JE, Levin LS, Lemasters GK, . 1998. Longitudinal estimates of pulmonary function in refractory ceramic fiber manufacturing workers. Am J Respir Crit Care Med 157(4 Pt 1):1226–1233.9563743
*Longley EO, Jones RC. 1966. Fiberglass conjunctivitis and keratitis. Arch Environ Health 13:790–793.5924066
Luce D, Leclerc A, Begin D, . 2002. Sinonasal cancer and occupational exposures: A polled analysis of 12 case-control studies. Cancer Causes Control 13:147–157.11936821
Luoto K, Holopainen M, Perander M, . 1996. Cellular effects of particles-impact of dissolution on toxicity of man-made mineral fibers. Cent Eur J Public Health 4:29–32.9167055
*Luoto K, Holopainen M, Sarataho M, . 1997. Comparison of cytotoxicity of man-made vitreous fibres. Ann Occup Hyg 41(1):37–50.9072949
Luoto K, Holopainen M, Savolainen K. 1994. Scanning electron microscopic study on the changes in the cell surface morphology of rat alveolar macrophages after their exposure to man-made vitreous fibers. Environ Res 66:198–207.8055841
Luoto K, Holopainen M, Savolainen K. 1995. Durability of man-made vitreous fibres as assessed by dissolution of silicon, iron and aluminium in rat alveolar macrophages. Ann Occup Hyg 39(6):855–867.
Ma Z, Otsuki T, Tomokuni A, . 1999. Man-made mineral fibers induce apotosis of human peripheral blood mononuclear cells similarly to chrysotile B. Int J Mol Med 4(6):633–637.10567675
Maltoni C, Minardi F, Soffritti M, . 1991. Long-term carcinogenicity bioassays on industrial chemicals, and man-made mineral fibers, at the Bentivoglio (BT) Laboratories of the Bologna Institute of Oncology: Premises, programs, and results. Toxicol Ind Health 7(516):63–94.1780902
*Marchand JL, Luce D, Lecierc A, . 2000. Laryngeal and hypopharyngeal cancer and occupational exposure to asbestos and man-made vitreous fibers: Results of a case-control study. Am J Ind Med 37(6):581–589.10797501
*Marchant GE, Amen MA, Bullock CH, . 2002. A synthetic vitreous fiber (SVF) occupational exposure database: Implementing the SVF health and safety partnership program. Appl Occup Environ Hyg 17:276–285.11942671
Marconi A, Corradetti E, Mannozzi A. 1987. Concentrations of man-made vitreous fibres during installation of insulation materials aboard ships at Ancona naval dockyards. Ann Occup Hyg 31(4B):595–599.
*Marks-Konczalik J, Gillissen A, Jaworska M, . 1998. Induction of manganese superoxide dismutase gene expression in bronchoepithelial cells after rockwool exposure. Lung 176(3):165–180.9638637
*Marsh GM, Buchanich JM, Youk AO. 2001a. Historical cohort study of US man-made vitreous fiber production workers. VI. Respiratory system cancer standardized mortality ratios adjusted for the confounding effect of cigarette smoking. J Occup Environ Med 43(9):803–808.11561363
*Marsh GM, Enterline PE, Stone RA, . 1990. Mortality among a cohort of U.S. man-made mineral fiber workers: 1985 follow-up. J Occup Environ Med 32:594–604.
*Marsh GM, Gula MJ, Youk AO, . 2001b. Historical cohort study of U.S. man-made vitreous fiber production workers: II. Mortality from mesothelioma. J Occup Environ Med 43(9):757–766.11561359
Marsh GM, Stone RA, Youk AO, . 1997. Cancer mortality among man-made vitreous fiber production workers. Letter to the editor. Epidemiology 9(2):218–220.
*Marsh GM, Youk AO, Stone RA, . 2001c. Historical cohort study of US man-made vitreous fiber production workers: I. 1992 fiberglass cohort follow-up: Initial findings. J Occup Environ Med 43(9):741–756.11561358
Mast RW, Hesterberg TW, Glass LR, . 1994. Chronic inhalation and biopersistence of refractory ceramic fiber in rats and hamsters. Environ Health Perspect Suppl 102(5):207–209.
*Mast RW, Maxim LD, Utell MJ, . 2000. Refractory ceramic fiber: Toxicology, epidemiology, and risk analyses- A review. Inhal Toxicol 12(5):359–399.
*Mast RW, McConnell EE, Hesterberg TW, . 1995b. Multiple-dose chronic inhalation toxicity study of size-separated kaolin refractory ceramic fiber in male Fischer 344 rats. Inhal Toxicol 7(4):469–502.21539475
*Mast RW, McConnell EE, Anderson R, . 1995a. Studies on the chronic toxicity (inhalation) of four types of refractory ceramic fiber in male Fischer 344 rats. Inhal Toxicol 7:425–467.21539476
*Mattson SM. 1994. Glass fiber dissolution in simulated lung fluid and measures needed to improve consistency and correspondence to in vivo dissolution. Environ Health Perspect 102:87–90.
*Maxim LD, McConnell EE. 2001. Interspecies comparisons of the toxicity of asbestos and synthetic vitreous fibers: A weight-of-the-evidence approach. Regul Toxicol Pharmacol 33(3):319–342.11407935
*Maxim LD, Allshouse JN, Chen SH, . 2000a. Workplace monitoring of refractory ceramic fiber in the United States. Regul Toxicol Pharmacol 32(3):293–309.11162723
Maxim LD, Allshouse JN, Kelly WP, . 1997. A multiyear workplace-monitoring program for refractory ceramic fibers: Findings and conclusions. Regul Toxicol Pharmacol 26(2):156–171.9356279
Maxim LD, Allshouse JN, Venturin DE. 2000b. The random-effects model applied to refractory ceramic fiber data. Regul Toxicol Pharmacol 32(2):190–199.11067775
Maxim LD, Boymel P, Chase GR, . 2002. Indices of fiber biopersistence and carcinogen classification for synthetic vitreous fibers (SVFs). Regul Toxicol Pharmacol 35:357–378.12202051
*Maxim LD, Eastes W, Hadley JG, . 2003a. Fiber glass and rock/slag wool exposure of professional and do-it-yourself installers. Regul Toxicol Pharmacol 37:28–44.12662907
*Maxim LD, Kelly WP, Walters T, . 1994. A multiyear workplace-monitoring program for refractory ceramic fibers. Regul Toxicol Pharmacol 20:S200–S215.7724851
Maxim LD, Mast RW, Utell MJ, . 1999a. Hazard assessment and risk analysis of two new synthetic vitreous fibers. Regul Toxicol Pharmacol 30(1):54–74.10464047
*Maxim LD, Venturin D, Allshouse JN. 1999b. Respirable crystalline silica exposure associated with the installation and removal of RCF and conventional silica-containing refractories in industrial furnaces. Regul Toxicol Pharmacol 29(1):44–63.10051418
*Maxim LD, Yu CP, Oberdorster G, . 2003b. Quantitative risk analyses for RCF: Survey and synthesis. Regul Toxicol Pharmacol 38:400–416.14623489
*Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
McClellan RO. 1994. Assessing health risks of synthetic vitreous fibers: An integrative approach. Regul Toxicol Pharmacol 20(9):S121–S134.7724844
McClellan RO, Hesterberg TW. 1994. Role of biopersistence in the pathogenicity of man-made fibers and methods for evaluating biopersistence: A summary of two round-table discussions. Environ Health Perspect 102:277–283.
McConnell EE. 1996. Commentary on “Fibrous glass and lung cancer”. Letter to the editor. Am J Ind Med 30:109–110.8837693
McConnell EE. 2000. A science-based paradigm for the classification of synthetic vitreous fibers. Regul Toxicol Pharmacol 32(1):14–21.11029264
*McConnell EE, Axten C, Hesterberg TW, . 1999. Studies on the inhalation toxicology of two fiberglasses and amosite asbestos in the Syrian golden hamster. Part II. Results of chronic exposure. Inhal Toxicol 1(9):785–835.
*McConnell EE, Kampstrup O, Musselman R, . 1994. Chronic inhalation study of size-separated rock and slag wool insulation fibers in Fischer 344/N rats. Inhal Toxicol 6:571–614.
*McConnell EE, Mast RW, Hesterberg TW, . 1995. Chronic inhalation toxicity of a kaolin-based refractory ceramic fiber in Syrian golden hamsters. Inhal Toxicol 7:503–532.
*McDonald AD, McDonald JC, Rando RJ, . 2001. Cohort mortality study of North American industrial sand workers. I. Mortality from lung cancer, silicosis and other causes. Ann Occup Hyg 45(3):193–199.11295142
McDonald JC. 1998. Mineral fibre persistence and carcinogenicity. Ind Health 36:372–375.9810152
*McDonald JC, Armstrong BG, Edwards CW, . 2001. Case-referent survey of young adults with mesothelioma: I. Lung analyses. Ann Occup Hyg 45(7):513–518.11583653
*McDonald JC, Case BW, Enterline PE, . 1990. Lung dust analysis in the assessment of past exposure of man-made mineral fibre workers. Ann Occup Hyg 34:427–441.2281888
*Meeker GP, Brownfield IK, Clark RN, . 2001. The chemical composition and physical properties of amphibole from Libby, Montana: a progress report. Poster presentation, 2001. Asbestos Health Effects Conference. Sponsored by U.S. Environmental Protection Agency, May 24-25. San Francisco, CA.
*Melton CW, Anderson SJ, Dye CF, . 1978. Development of a rapid analytical method for determining asbestos in water. Gov Rep Announce Index (U.S.) 1979, 79(11), 80.
*Mentzer, KD. 1999. Written communication (May 18, 1999) to Dr. Adam Finkel, Director of Health Standards, OSHA regarding voluntary health and safety partnership program for fiber glass, rock and slag wool fiber products.
Miettinen OS, Rossiter CE. 1990. Man-made mineral fibers and lung cancer. Scand J Work Environ Health 16(4):221–231.2389128
*Milby TH, Wolf CR. 1969. Respiratory tract irritation from fibrous glass inhalation. J Occup Med 11(8):409–410.5795599
Miller BG, Jones AD, Searl A, . 1999. Influence of characteristics of inhaled fibres on development of tumours in the rat lung. Ann Occup Hyg 43(3):167–179.10366898
Miller BG, Searl A, Davis JMG, . 1999. Influence of fibre length, dissolution and biopersistence on the production of mesothelioma in the rat peritoneal cavity. Ann Occup Hyg 43(3):155–166.10366897
Miller K, Hudspith BN, Meredith C. 1994. The effect of MMMF on the kinetics of cytokine expression in murine lung populations: Role in fibre-induced disease. NATO ASI Ser H 85:79–90.
*Miller ME, Lees PSJ, Breysse PN. 1995. A comparison of airborne man-made vitreous fiber concentrations before and after installation of insulation in a new construction housing. Appl Occup Environ Hyg 10(3):182–187.
Milton DK, Walters MD, Hammond K, . 1996a. Worker exposure to endotoxin, phenolic compounds, and formaldehyde in a fiberglass insulation manufacturing plant. Am Ind Hyg Assoc J 57:889–896.8865598
Milton DK, Wypij D, Kriebel D, . 1996b. Endotoxin exposure-response in a fiberglass manufacturing facility. Am J Ind Med 29:3–13.8808037
*Minamoto K, Nagano M, Inaoka T, . 2002. Skin problems among fiber-glass reinforced plastics factory workers in Japan. Ind Health 40:42–50.11926514
Mirer FE, Park RM. 1993. A case-control study of malignant and non-malignant disease among employees of a fiberglass manufacturing facility. Comments. Br J Ind Med 50(3):287.
Mitchell RI, Donofrio DJ, Moorman WJ. 1986. Chronic inhalation toxicity of fibrous glass in rats and monkeys. J Am Coll Toxicol 5(6):545–575.
Miyamoto K, Hiramatsu K, Ohtaki Y, . 1995. Effects of gomisin A on the promotor action and serum bile acid concentration in hepatocarcinogenesis induced by 3’-methyl-4-dimethylaminoazobenzene. Biol Pharm Bull 18(10):1443–1445.8593453
*Mohr U, Pott F, Vonnahme FJ. 1984. Morphological aspects of mesotheliomas after intratracheal instillations of fibrous dusts in Syrian golden hamsters. Exp Pathol 26(3):179–183.6542873
Monchaux G, Bignon J, Hirsch A, . 1982. Translocation of mineral fibres through the respiratory system after injection into the pleural cavity of rats. Ann Occup Hyg 26(1–4):309–318.6295242
*Monchaux G, Bignon J, Jaurand MC, . 1981. Mesotheliomas in rats following inoculation with acid-leached chrysotile asbestos and other mineral fibers. Carcinogenesis 2(3):229–236.6268324
Moolgavkar SH, Brown RC, Turim J. 2001a. Biopersistence, fiber length, and cancer risk assessment for inhaled fibers. Inhal Toxicol 13(9):755–772.11570360
Moolgavkar SH, Luebeck EG, Turim J, . 2000. Lung cancer risk associated with exposure to man-made fibers. Drug Chem Toxicol 23(1):223–242.10711399
Moolgavkar SH, Turim J, Brown RC, . 2001b. Long man-made fibers and lung cancer risk. Regul Toxicol Pharmacol 33:138–146.11350196
Moore MA, Boymel PM, Maxim LD. 2002. Categorization and nomenclature of vitreous silicate wools. Regul Toxicol Pharmacol 35(1):1–13.11846631
*Morgan RW. 1981. Mortality study of fibrous glass production workers. Arch Environ Health 36:179–183.7271323
Morgan A. 1994. In vivo evaluation of chemical biopersistence of man-made mineral fibers. Environ Health Perspect 102:127–131.
*Morgan A. 1995. Deposition of inhaled asbestos and man-made mineral fibers in the respiratory tract. Ann Occup Hyg 39(5):747–758.8526405
*Morgan A, Holmes A. 1980. Concentrations and dimensions of coated and uncoated asbestos fibres in the human lung. Br J Ind Med 37:25–32.7370190
Morgan A, Holmes A. 1984. Solubility of rockwool fibres in vivo and the formation of pseudo-asbestos bodies. Ann Occup Hyg 28(3):307–314.6508081
Morgan A, Holmes A. 1986. Solubility of asbestos and man-made mineral fibers in vitro and in vivo: Its significance in lung disease. Environ Res 39:475–484.3007107
*Morgan A, Black A, Evans N, . 1980. Deposition of sized glass fibres in the respiratory tract of the rat. Ann Occup Hyg 23:353–366.7258930
*Morgan A, Collier CG, Morris KJ, . 1993. A radioactive tracer technique to determine in vivo the number of fibers in the lungs of rats following their administration by intratracheal instillation. Environ Res 182–190.
Morgan A, Davis JA, Mattson SM, . 1994b. Effect of chemical composition on the solubility of glass fibres in vivo and in vitro. Ann Occup Hyg 38:609–617.
*Morgan A, Holmes A, Davison W. 1982. Clearance of sized glass fibres from the rat lung and their solubility in vivo Ann Occup Hyg 25(3):317–331.7181257
*Morgan A, Morris KJ, Launder KA, . 1994a. Retention of glass fibers in the rat trachea following administration by intratracheal instillation. Inhal Toxicol 6:241–251.
*Morgan A, Talbot RJ, Holmes A. 1978. Significance of fibre length in the clearance of asbestos fibres from the lung. Br J Ind Med 35:146–153.656339
Morimoto Y, Tanaka I. 2001. In vivo studies of man-made mineral fibers- Fibrosis-related factors. Ind Health 39(2):106–113.11341539
*Morimoto Y, Kido M, Tanaka I, . 1993. Synergistic effects of mineral fibres and cigarette smoke on the production of tumour necrosis factor by alveolar macrophages of rats. Br J Ind Med 50(10):955–960.8217857
Morimoto Y, Tsuda T, Hirohashi M, . 1999. Effects of mineral fibers on the gene expression of proinflammatory cytokines and inducible nitric-oxide synthase in alveolar macrophages. Ind Health 37(3):329–334.10441905
Morimoto Y, Tsuda T, Hori H, . 1999. Combined effect of cigarette smoke and mineral fibers on the gene expression of cytokine mRNA. Environ Health Perspect 107(6):495–500.
Morimoto Y, Tsuda T, Nakamura H, . 1997. Expression of matrix metalloproteinases, tissue inhibitors of metalloproteinases, and extracellular matrix mRNA following exposure to mineral fibers and cigarette smoke in vivo. Environ Health Perspect Suppl 105(5):1247–1251.9400732
Morimoto Y, Tsuda T, Yamato H, . 2001. Comparison of gene expression of cytokines mRNA in lungs of rats induced by intratracheal instillation and inhalation of mineral fibers. Inhal Toxicol 13(7):589–601.11452356
Morris GF, Brody AR. 1999. Stressing fibrogenesis in cell culture. Am J Respir Cell Mol Biol 21(4):447–448.10502552
Morris KJ, Collier CG, Eastes W, . 1996. Comparison of biopersistence of experimental glass fibres in the lung and peritoneal cavity. Exp Toxicol Pathol 48(6):490–493.8954329
*Morris KJ, Launder KA, Morgan A, . 1995. Preliminary data from investigations of the in vivo biopersistence of three experimental glass fibres of varying chemical composition. Exp Toxicol Pathol 47(2–3):179–182.7580105
*Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5:485–527.
Morton WE. 2002. Comment on historical cohort study of U.S. man-made vitreous fiber production workers. Letters to the editor. J Occup Environ Med 44(2):106–108.11851211
Mossman BT. 1988. Carcinogenic potential of asbestos and nonasbestos fibers. J Environ Sci Health Part C Environ Carcinogen Rev 6(2):151–195.
*Mossman BT, Churg A. 1998. Mechanisms in the pathogenesis of asbestosis and silicosis. Am J Respir Crit Care Med 157:1666–1680.9603153
Moulin JJ, Mur JM, Wild P, . 1986. Oral cavity and laryngeal cancers among man-made mineral fiber production workers. Scand J Work Environ Health 12(9):27–31.3961439
*Moulin JJ, Wild P, Mur JM, . 1988. Respiratory health assessment by questionnaire of 2024 workers involved in man-made miner fiber production. Int Arch Occup Environ Health 61(3):171–178.2851556
*Muhle H, Bellmann B. 1995. Biopersistence of man-made vitreous fibres. Ann Occup Hyg 39(5):655–660.8526396
*Muhle H, Bellmann B. 1997. Significance of the biodurability of man-made vitreous fibers to risk assessment. Environ Health Perspect 105:1045–1047.9400698
Muhle H, Mangelsdorf I. 2003. Inahalation toxicity of mineral particles: Critical appraisal of endpoints and study design. Toxicol Lett 140–141:223–228.
Muhle H, Pott F. 2000. Asbestos as reference material for fibre-induced cancer. Int Arch Occup Environ Health 73:S53–S59.10968562
Muhle H, Bellmann B, Pott F. 1994. Comparative investigations of the biodurability of mineral fibers in the rat lung. Environ Health Perspect 102:163–168.7882923
*Muhle H, Pott F, Bellman B, Takenaka S, . 1987. Inhalation and injection experiments in rats to test the carcinogenicity of MMMF. Ann Occup Hyg 31(4B):755–764.2835926
Murata-Kamiya N, Tsutsui T, Fujino A, . 1997. Determination of carcinogenic potential of mineral fibers by 8-hydroxydeoxyguanosine as a marker of oxidative DNA damage in mammalian cells. Int Arch Occup Environ Health 70:321–326.9352335
Murphy GB. 1961. Fiber glass pneumoconiosis. Arch Environ Health 3:102–108.
Musselman R. 1992. A case-control study of lung cancer in a cohort of workers potentially exposed to slog wool fibres. Br J Ind Med 49(6):454.1606037
*Musselman R, Miiller W, Eastes W, . 1994a. Biopersistence of crocidolite versus man-made vitreous fibers in rat lungs after brief exposures. In: Mohr U, Dungworth DL, Mauderly JL, ., eds. Toxic and carcinogenic effects of solid particles in the respiratory tract. Washington, DC: ILSI Press, 451–454.
*Musselman RP, Miiller WC, Eastes W, . 1994b. Biopersistences of man-made vitreous fibers and crocidolite fibers in rat lungs following short-term exposures. Environ Health Perspect Suppl 102(5):139–143.
*Myojo T. 1987. Deposition of fibrous aerosol in model bifurcating tubes. J Aerosol Sci 18(3):337–347.
Myojo T. 1990. The effect of length and diameter on the disposition of fibrous aerosol in a model lung bifurcation. J Aerosol Sci 21(5):651–659.
Myojo T, Takaya M. 2001. Estimation of fibrous aerosol deposition in upper bronchi based on experimental data with model bifurcation. Ind Health 39:141–149.11341544
Nadeau D, Fouquette-Couture L, Paradis D, . 1987. Cytotoxicity of respirable dusts from industrial minerals; comparison of two naturally occurring and two man-made silicates. Drug Chem Toxicol 10:49–86.2824167
*NAIMA. 2002. Fiber glass and slag wool insulations- materials for a sustainable planet. North American Insulation Manufacturers Association. Publication No. 12.
*NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press.
*Nasr ANM, Ditchek T, Scholtens PA. 1971. The prevalence of radiographic abnormalities in the chests of fiber glass workers. J Occup Med 13(8):371–376.5564764
*Navy Environment Health Center. 1997. Man-made vitreous fibers. Technical Manual NEHC-TM6290-1. Rev. A.
Nejjari A, Fournier J, Pezerat H, . 1993. Mineral fibres: Correlation between oxidizing surface activity and DNA base hydroxylation. Br J Ind Med 50(6):501–504.8329314
*Newball HH, Brahim SA. 1976. Respiratory response to domestic fibrous glass exposure. Environ Res 12:201–207.986939
*NIOSH. 1976. Occupational exposure to fibrous glass. Proceedings of a Symposium. Washington, DC: National Institute for Occupational Safety and Health, 33–61, 83–89, 193–204.
*NIOSH. 1977. Occupational exposure to fibrous glass-criteria for a recommended standard. National Institute for Occupational Safety and Health.
*NIOSH. 1992. Pocket guide to chemical hazards. National Institute for Occupational Safety and Health.
*NIOSH. 1994a. Asbestos (bulk) by PLM. NIOSH Manual of Analytical Methods (NMAM), Fourth Edition, 8/15/94. National Institute for Occupational Safety and Health.
NIOSH. 1994b. NIOSH manual of analytical methods. NIOSH method 7400. 4^th^ ed. National Institute for Occupational Safety and Health.
*NIOSH. 1999. Work-related lung disease surveillance report 1999. U.S. Department of Health and Human Services, Division of Respiratory Disease Studies. National Institute for Occupational Safety and Health. Washington, DC.
*NIOSH. 2002. NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/default.html. May 07, 2002.
*NRC. 1993. National Research Council. Pesticides in the diets of infants and children. Washington, DC: National Academy Press.
*NRC Subcommittee on Manufactured Vitreous Fibers. 2000. Review of the U.S. Navy’s Exposure Standard for manufactured vitreous fibers. National Academy of Sciences, National Research Council, Washington, DC: National Academy Press.
*NTP. 1994. 7^th^ Report on carcinogens. National Toxicology Program. http://ntp-server.niehs.nih.gov/Main_pages/NTP_7RoC_pg.html. May 07, 2002.
*NTP. 1998. 8^th^ Report on carcinogens. National Toxicology Program. http://ntp-server.niehs.nih.gov/Main_pages/NTP_8RoC_pg.html. May 07, 2002.
*NTP. 2000. 9^th^ Report on carcinogens. National Toxicology Program. http://ehp.niehs.nih.gov/roc/toc9.html. May 07, 2002.
*NTP. 2002. 10^th^ Report on carcinogens. National Toxicology Program. http://ehp.niehs.nih.gov/roc/toc9.html. January 17, 2004.
*Oberdörster G. 1994. Respiratory tract dosimetry of particles: implications for setting of exposure concentrations and extrapolation modeling. Proceedings of an international symposium: IPCS Joint Series No. 18, 83–110.
*Oberdörster G. 2000. Determinants of the pathogenicity of man-made vitreous fibres (MMVF) Int Arch Occup Environ Health 73:S60–S68.10968563
Oberdörster G. 2002. Toxicokinetics and effects of fibrous and nonfibrous particles. Inhal Toxicol 14:29–56.12122559
Ohyama M, Otake T, Morinaga K. 2000. The chemiluminescent response from human monocyte-derived macrophages exposed to various mineral fibers of different sizes. Ind Health 38(3):289–293.10943076
Ohyama M, Otake T, Morinaga K. 2001. Effect of size of man-made and natural mineral fibers on chemiluminescent response in human monocyte-derived macrophages. Environ Health Perspect 109(10):1033–1038.11675268
Ojajarvi IA, Partanen TJ, Ahblom A, . 2000. Occupational exposures and pancreatic cancer: A meta-analysis. Occup Environ Med 57(5):316–324.10769297
*Okabe K, Murthy GGK, Vallarino JA, . 1997. Deposition efficiency of inhaled fibers in the hamster lung. Inhal Toxicol 9(2):85–98.
Okabe K, Vallarino JA, Murthy GGK, . 1996. Dissolution of slagwool fibers in the filter clearing and mounting step in preparation for counting. Inhal Toxicol 8(3):263–270.
Okayasu R, Wu L, Hei TK. 1999. Biological effects of naturally occurring and man-made fibres: in vitro cytotoxicity and mutagenesis in mammalian cells. Br J Cancer 79(9/10):1319–1324.10188871
*Olsen JH, Jensen OM. 1984. Cancer incidence among employees in one mineral wool production plant in Denmark. Scand J Work Environ Health 10:17–24.6547541
*Olsen JH, Jensen OM, Kampstrup O. 1986. Influence of smoking habits and place of residence on the risk of lung cancer among workers in one rock-wool producing plant in Denmark. Scand J Work Environ Health 12:48–52.3798053
*Ong T, Lui Y, Zhong B-Z, . 1997. Induction of micronucleated and mutinucleated cells by man-made fibers in vitro in mammalian cells. J Toxicol Environ Health 50(4):409–414.9120877
Osgood CJ. 1994. Refractory ceramic fibers (RFCs) induce germline aneuploidy in Drosophila oocytes. Mutat Res 324(1–2):23–27.7515466
*OSHA. 1992. U.S. Department of Labor, Occupational Safety and Health Administration. 57:7877–7878, 24310–24331, 49657–49661.
*OSHA. 1999. OSHA endorses major agreement to protect workers exposed to fiberglass insulation. Occupational Safety and Health Administration. http://www.osha-slc.gov/media/oshanews/may99/trade-19990518.html. May 07, 2002.
OSHA. 2001a. Asbestos. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1001. http://www.osha.gov/pls/oshaweb/owa…ARDS&p-id=9995&p-text-version=FALSE. May 07, 2002.
*OSHA. 2001b. Synthetic mineral fibers. Occupational Safety and Health Administration. http://www.osha.gov/SLTC/syntheticmineralfibers/index.html. May 07, 2002.
*OSHA. 2002. Synthetic mineral fibers. Occupational Safety and Health Administration. http://www.osha.gov/oshinfo/priorities/synthetic.html. May 07, 2002.
*Oshimura M, Hesterberg TW, Tsutsui T, . 1984. Correlation of asbestos-induced cytogenic effects with cell transformation of Syrian hamster embryo cells in culture. Cancer Res 44(11):5017–5022.6091868
*Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Pang TWS. 2000. Precision and accuracy of asbestos fiber counting by phase contrast microscopy. Environ Sci Technol 61(4):529–538.
*Pang TWS, Schonfeld-Starr FA, Patel K. 1989. An improved membrane filter technique for evaluation of asbestos fibers. Am Ind Hyg Assoc J 50(3):174–190.
Pelin K, Kivipensas P, Linnainmaa K. 1995. Effects of asbestos and man-made vitreous fibers on cell division in cultured human mesothelial cells in comparison to rodent cells. Environ Mol Mutagen 25:118–125.7698105
*Peraud A, Riebe-Imre M. 1994. Toxic and chromosomal-damaging effects of natural and man-made mineral fibers in epithelial lung cells in vitro. In: Dungworth DL, Mauderly JL, Oberdorster G, eds. Toxic and carcinogenic effects of solid particles in the respiratory tract. Washington, DC: ILSI Press, 569–574.
*Perrault G, Dion C, Cloutier Y. 1992. Sampling and analysis of mineral fibers on construction sites. Appl Occup Environ Hyg 7(5):323–326.
*Petersen R, Sabroe S. 1991. Irritative symptoms and exposure to mineral wool. Am J Ind Med 20(1):113–122.1831004
*Phalen RF, Oldham MJ, Beaucage CB, . 1985. Postnatal enlargement of human tracheobronchial airways and implications for particle deposition. Anat Rec 212:368–380.4073554
*Pickrell JA, Hill JO, Carpenter RL, . 1983. In vitro and in vivo response after exposure to man-made mineral and asbestos insulation fibers. Am Ind Hyg Assoc J 44(8):557–561.6312789
Pigott GH, Ishmael J. 1981. An assessment of the fibrogenic potential of 2 refractory fibers by intraperitoneal injection in rats. Toxicol Lett 8(3):153–164.7245251
Pigott GH, Ishmael J. 1992. The effects of intrapleural injections of alumina and aluminosilicate (ceramic) fibers. Int J Exp Pathol 73:137–146.1571274
*Plato N, Gustavsson P, Krantz S. 1997. Assessment of past exposure to man-made vitreous fibers in the Swedish prefabricated house industry. Am J Ind Med 32(4):349–354.9258388
Plato N, Krantz S, Andersson L, . 1995a. Characterization of current exposure to man-made vitreous fibres (MMVF) in the prefabricated house industry in Sweden. Ann Occup Hyg 39(2):167–179.7741414
Plato N, Krantz S, Gustavsson P, . 1995b Fiber exposure assessment in the Swedish rock wool and slag wool production industry in 1938-1990. Scand J Work Environ Health 21(5):345–352.8571090
*Plato N, Westerholm P, Gustavsson P, . 1995c. Cancer incidence, mortality and exposure-response among Swedish man-made vitreous fiber production workers. Scand J Work Environ Health 21(5):353–361.8571091
*Pohlabein H, Jockel K-H, Bruske-Hohlfeld I, . 2000. Lung cancer and exposure to man-made vitreous fibers: Results from a pooled case-control study in Germany. Am J Ind Med 37:469–477.10723041
*Possick PA, Gellin GA, Key MM. 1970. Fibrous glass dermatitis. Am Ind Hyg Assoc J 37:12–15.
Pott F. 1980. Animal experiments on biological effects of mineral fibres. In: Wagner JC, Davis W, eds. Biological effects of mineral fibers. IARC Sci Publ 30:261–272.
Pott F. 1995. Detection of mineral fibre carcinogenicity with the intraperitoneal test recent results and their validity. Ann Occup Hyg 39(5):771–779.8526407
Pott F, Roller M. 1998. [How far can carcinogenicity studies of fiber types be substituted by data on their biopersistence?] Geharstoffe Reinhalt Luft 58(3):85–91. (German)
Pott F, Dungworth DL, Heinrich U, . 1994. Lung tumours in rats after intratracheal instillation of dusts. Ann Occup Hyg 38:357–363.
Pott F, Friedrichs KH, Huth F. 1975. [Carcinogenic effects of fibrous dusts.] EUR 2:715–724. (German)
*Pott F, Freidrichs K-H, Huth F. 1976. Results of animal experiments concerning the carcinogenic effect of fibrous dusts and their interpretation with regard to the carcinogenesis in humans. Zbl Bakt Hyg I Abt Orig B 162:467–505.
Pott F, Huth F, Friedrichs KH. 1974. Tumorigenic effect of fibrous dusts in experimental animals. Environ Health Perspect 9:313–315.4377876
Pott F, Huth F, Spurny K. 1980. Tumour induction after intraperitoneal injection of fibrous dusts. In: Wagner JC, Davis W, eds. Biological effects of mineral fibres. IARC Sci Publ 30:337–342.
Pott F, Roller M, Kamino K, . 1994. Significance of durability of mineral fibers for their toxicity and carcinogenic potency in the abdominal cavity of rats in comparison with the low sensitivity of inhalation studies. Environ Health Perspect 102:145–150.
Pott F, Roller M, Ziem U, . 1989. Carcinogenicity studies on natural and man-made fibres with the intraperitoneal test in rats. IARC Sci Publ 90:173–179.
*Pott F, Schllipkoter HW, Ziem U. 1984. New results from implantation experiments with mineral fibres. Proceedings of the World Health Organization Conference, 286–302.
Pott F, Ziem U, Mohr U. 1983. Lung carcinomas and mesotheliomas following intratracheal instillation of glass fibres and asbestos. Report held on the VI^th^ International Pneumoconiosis Conference, September 20-23, 1983.
*Pott F, Ziem L, Reiffer FJ, . 1987. Carcinogenicity studies on fibres, metal compounds, and some other dusts in rats. Exp Pathol 32:129–152.3436395
*Potter RM, Mattson SM. 1991. Glass fibre dissolution in a physiological saline solution. Glastech Ber 64:16–28.
*Quinn MM, Smith TJ, Youk AO, . 2001. Historical cohort study of US man-made vitreous fiber production workers: VIII. Exposure-specific job analysis. J Occup Environ Med 43:824–834.11561365
Randall REG, DuToit RSJ. 1994. The retention and clearance of glass fibre and different varieties of asbestos by the lung. Ann Occup Hyg 38:757–761.
*Renne RA, Eldridge SR, Lewis TR, . 1985. Fibrogenic potential of intratracheally instilled quartz, ferric oxide, fibrous glass, and hydrated alumina in hamsters. Toxicol Pathol 13:306–314.3010436
Rice CH, Lockey JE, Lemasters GK, . 1997. Estimation of historical and current employee exposure to refractory ceramic fibers during manufacturing and related operations. Appl Occup Environ Hyg 12(1):54–61.
Riebe-Imre M, Aufderheide M, Emura M, . 1994. Comparative studies with natural and man-made mineral fibres in vitro and in vivo. NATO ASI Ser H 85:273–284.
*Rindel A, Bach E, Breum NO, . 1987. Correlating health effects with indoor air quality in kindergartens. Int Arch Occup Environ Health 59:363–373.3610336
*Robinson CF, Dement JM, Ness GO, . 1982. Mortality patterns of rock and slag mineral wool production workers: an epidemiological and environmental study. Br J Ind Med 39(1):45–53.6279138
*Rodelsperger K, Woitowitz HJ. 1995. Airborne fibre concentrations and lung burden compared to the tumour response in rats and humans exposed to asbestos. Ann Occup Hyg 39(5):719–725.
*Rodelsperger K, Jockel K-H, Pohlabein H, . 2001. Asbestos and man-made vitreous fibers as risk factors for diffuse malignant mesothelioma: Results from a German hospital-based case-control study. Am J Ind Med 39(3):262–275.11241559
*Roggli VL. 1989. Nonasbestos mineral fibers in human lungs. Microbeam Analysis 24:57–59.
Roller M, Pott F, Kamino K, . 1996. Results of current intraperitoneal carcinogenicity studies with mineral and vitreous fibres. Exp Toxicol Pathol 48:3–12.8919265
Roller M, Pott F, Kamino K, . 1997. Dose-response relationship of fibrous dusts in intraperitoneal studies. Environ Health Perspect Suppl 105(5):1253–1256.9400733
Rood AP. 1988. Size distribution of airborne ceramic fibres as determined by transmission electron microscopy. Ann Occup Hyg 32(2):237–240.3415145
Rood AP, Streeter RR. 1985. Size distributions of airborne superfine man-made mineral fibers determined by transmission electron microscopy. Am Ind Hyg Assoc J 46(5):257–261.4003277
Rossiter CE. 1993. Pulmonary effects of exposure to fine fiberglass: irregular opacities and small airways obstruction. Br J Ind Med 50:382–383.8494780
*Rossiter CE, Gilson JC, Sheers G, . 1994. Refractory ceramic fibre production workers. Analysis of radiograph readings. Ann Occup Hyg 38:731–738.
Rouyer E, Lehuede P, Chopinet M-H. 1995. Corrosion mechanisms of glass fibers by physiological fluid in in-vitro tests. Verre 1:621–624.
Rowe JN, Springer JA. 1986. Asbestos lung cancer risks: Comparison of animal and human extrapolations. Risk Anal 6(2):171–180.3615987
Ruotsalainen M, Hirvonen M-R, Luoto K. 1999. Production of reactive oxygen species by man-made vitreous fibres in human polymorphonuclear leukocytes. Hum Exp Toxicol 18(6):354–362.10413242
Rutten A, Bermudez E, Mangum J, . 1994a. Pleural pathology in hamsters and rats exposed to instilled man-made vitreous fibers. In: Dungworth DL, Mauderly JL, Oberdorster G, eds. Toxic and carcinogenic effects of solid particles in the respiratory tract. Washington, DC: ILSI Press, 595–598.
Rutten AA, Bermudez E, Mangum JB, . 1994b. Mesothelial cell proliferation induced by intrapleural instillation of man-made fibers in rats and hamsters. Fundam Appl Toxicol 23(1):107–117.7958554
Saffiotti U. 1998. Respiratory tract carcinogenesis by mineral fibres and dusts: models and mechanisms. Monaldi Arch Chest Dis 53(2):160–167.9689803
Sahle W, Laszlo I. 1996. Airborne inorganic fibre level monitoring by transmission electron microscope (TEM): Comparison of direct and indirect sample transfer methods. Ann Occup Hyg 40(1):29–44.9054300
*Sali D, Boffetta P, Andersen A, . 1999. Non-neoplastic mortality of European workers who produce man made vitreous fibres. Occup Environ Med 56:612–617.10615294
*Sanden A, Jarvholm B. 1986. Pleural plaques, respiratory symptoms and respiratory function in shipyard workers exposed to man-made mineral fibres. J Soc Occup Med 36:86–89.3762090
Saracci R. 1986. Ten years of epidemiologic investigations on man-made mineral fibers and health. Scand J Work Environ Health 12:5–11.
*Saracci R, Simonato L, Acheson ED, . 1984. Mortality and incidence of cancer of workers in the man made vitreous fibres producing industry: an international investigation at 13 European plants. Br J Ind Med 41:425–436.6498106
*Scansetti G, Pira E, Botta GC, . 1993. Asbestos exposure in a steam-electric generating plant. Ann Occup Hyg 37(6):645–655.
*Schneider T. 1986. Manmade mineral fibers and other fibers in the air and settled dust. Environ Int 12:61–65.
Schneider T, Skotte J. 1990. Fiber exposure reassessed with the new indices. Environ Res 51:108–116.2153537
*Schneider T, Stokholm J. 1981. Accumulation of fibres in the eyes of workers handling man-made mineral fiber products. Scand J Work Environ Health 7(7):271–276.7347912
*Schneider T, Burdett G, Martinon L, . 1996. Ubiquitous fiber exposure in selected sampling sites in Europe. Scand J Work Environ Health 22(4):274–284.8881016
Schneider T, Gibbs GW, Burdett G, . 1997. Testing fibre release from insulation products: Report on a workshop. Ann Occup Hyg 41(5):605–607.9332161
Schneider T, Husemoen T, Olsen E, . 1993. Airborne fibre concentration during standardized building insulation with bonded man-made vitreous fibre insulation material having different nominal diameters and oil content. Ann Occup Hyg 37(6):631–644.
*Schneider T, Nielsen O, Bredsdorff P, . 1990. Dust in buildings with man-made mineral fiber ceiling boards. Scand J Work Environ Health 16:434–439.2284592
Schneider T, Skotte J, Nissen P. 1985. Man-made mineral fiber size fractions and their interrelation. Scand J Work Environ Health 11(2):117–122.4001900
*Scholze H, Conradt R. 1987. An in vitro study of the chemical durability of siliceous fibres. Ann Occup Hyg 31(4B):683–692.
Schuman LD, Infante PF. 1993. Synthetic mineral fibers. J Occup Med 35(12):1173–1177.8113917
*Searl A. 1997. A comparative study of the clearance of respirable para-aramid, chrysotile and glass fibres from rat lungs. Ann Occup Hyg 41:217–233.9155241
Searl A, Cullen RT. 1997. An enzymatic tissue digestion method for fibre biopersistence studies. Ann Occup Hyg 41(6):721–727.9375530
*Searl A, Buchanan D, Cullen RT, . 1999. Biopersistence and durability of nine mineral fibre types in rat lungs over 12 months. Ann Occup Hyg 43(3):143–153.10366896
*Sebastien P, Vergnon JM, Blanchard O, . 1994. Durability of ceramic fibres in the human lung. Preliminary results. Ann Occup Hyg 38:723–730.
Sernau R, Cortina T, Zito M, . 1984. Genotoxicity of asbestos and fiberglass in the Chinese hamster ovary (CHO) HGRPT forward mutation and sister chromatid exchange assays. Environ Mutagen 6:422–423.
*Setchell BP, Waites GMH. 1975. The blood-testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Philadelphia, PA: WB Saunders, 222–238.
*Shannon HS, Hayes M, Julian JA, . 1984. Mortality experience of glass fibre workers. Br J Ind Med 41:35–38.6691934
*Shannon HS, Jamieson E, Julian JA, . 1987. Mortality experience of Ontario glass fibre workers - extended follow-up. Ann Occup Hyg 31(4B):657–662.3450232
*Shannon HS, Jamieson E, Julian JA, . 1990. Mortality of glass filament (textile) workers. Br J Ind Med 47(5):533–536.2393633
Shaw GR, Connell DW. 1994. Prediction and monitoring of the carcinogenicity of polycyclic aromatic compounds (PACs). Rev Environ Contam Toxicol 135:1–62.8171214
*Simonato L, Fletcher AC, Cherrie J, . 1986a. The man-made mineral fiber European historical cohort study. Scand J Work Environ Health 12:34–47.3798052
Simonato L, Fletcher AC, Cherrie J, . 1986b. Updating lung cancer mortality among a cohort of man-made mineral fibre production workers in seven European countries. Cancer Lett 30(2):189–200.3955541
*Simonato L, Fletcher AC, Cherrie JW, . 1987. The International Agency for Research on Cancer historical cohort study of MMMF production workers in seven European countries: Extension of the follow-up. Ann Occup Hyg 31(4B):603–623.3450230
*Sincock AM, Delhanty JDA, Casey G. 1982. A comparison of the cytogenetic response to asbestos and glass fibre in Chinese hamster and human cell lines. Mutat Res 101(3):257–268.7087986
*Sjogren B. 2000. Non-neoplastic mortality of European workers who produce man-made vitreous fibres. Occup Environ Med 57:284–288.
*Smith DM, Ortiz LW, Archuleta RF, . 1987. Long-term health effects in hamsters and rats exposed chronically to man-made vitreous fibres. Ann Occup Hyg 31(4B):731–754.2835925
*Smith TJ, Quinn MM, Marsh GM, . 2001. Historical cohort study of US man-made vitreous fiber production workers: VII. Overview of the exposure assessment. J Occup Environ Med 43(9):809–823.11561364
*Spruny KR. 1994. Sampling, analysis, identification and monitoring of fibrous dusts and aerosols. Analyst 119:41–51.
Spurny KR, Pott F, Stober W, . 1983. On the chemical changes of asbestos fibers and MMMFs in biologic residence and in the environment: Part I. Am Ind Hyg Assoc J 44(11):833–845.
*Stam-Westerveld EB, Coenraads PJ, vanderValk PGM, . 1994. Rubbing test responses of the skin to man-made mineral fibres of different diameters. Contact Dermatitis 31:1–4.7924285
*Stanton MF, Wrench C. 1972. Mechanisms of mesothelioma induction with asbestos and fibrous glass. J Natl Cancer Inst 48:797–822.5058974
*Stanton WF, Layard M, Tegeris A, . 1977. Carcinogenicity of fibrous glass: Pleural response in the rat in relation to fiber dimension. J Natl Cancer Inst 58(3):587–597.839555
Steenland K, Stayner L. 1997. Silica, asbesots, man-made mineral fibers, and cancer. Cancer Causes Control 8:491–503.9498906
*Stöber W. 1972. Dynamic shape factors of nonspherical aerosol particles. In: Mercer TT, Morrow PE, Stober W, eds. Assessment of airborne particles. Springfield: Charles C. Thomas, 249–289.
*Stöber W, McClellan, RO. 1997. Pulmonary retention and clearance of inhaled biopersistent aerosol particles: Data-reducing interpolation models and models of physiologically based systems. Crit Rev Toxicol 27(6):539–598.9408732
*Stockholm J, Norn M, Schneider T. 1982. Ophthalmologic effects of man-made mineral fibers. Scand J Work Environ Health 8(3):185–190.6984224
Stone RA, Marsh GM, Youk AO, . 1996. Statistical estimation of exposure to fibres in jobs for which no direct measurements are available. Occup Hyg 3:91–101.
*Stone RA, Youk AO, Marsh GM, . 2001. Historical cohort study of US man-made vitreous fiber production workers: IV Quantitative exposure-response analysis of the nested case-control study of respiratory system cancer. J Occup Environ Med 43(9):779–792.11561361
Strubel G, Fraij B, Rodelsperger K, . 1986. Man-made mineral fibers in the working environment. Letter to the editor. Am J Ind Med 10(1):101–102.3740064
*Switala ED, Harlan RC, Schlaudecker DG, . 1994. Measurement of respirable glass and total fiber concentrations in the ambient air around a fiberglass wool manufacturing facility and a rural area. Regul Toxicol Pharmacol 20(3 part 2):S76–S88.7724859
Takahashi T, Munakata M, Takekawa H, . 1996. Pulmonary fibrosis in a carpenter with long-lasting exposure to fiberglass. Am J Ind Med 30:596–600.8909608
Tanaka I, Oyabu T, Ishimatsu S. 1994a. Pulmonary deposition and clearance of glass fiber in rat lungs after long-term inhalation. Environ Health Perspect 102:215–216.
Tanaka I, Shutou T, Ishimatsu S. 1994b. Pulmonary deposition and clearance of glass fibre in rats after continuous inhalation. Ann Occup Hyg 38:753–756.
Tanaka I, Yamato H, Oyabu T, . 2001. Biopersistence of man-made fibers by animal inhalation experiments in recent reports. Ind Health 39(2):114–118.11341540
*Tarvainen K, Jolanki R, Forsman-Gronholm L, . 1993. Exposure, skin protection and occupational skin diseases in the glass-fibre-reinforced plastics industry. Contact Dermatitis 29(3):119–127.8222622
*Teppo L, Kojonen E. 1986. Mortality and cancer risk among workers exposed to man-made mineral fibers in Finland. Scand J Work Environ Health 12:61–64.
*Thriene B, Sobottka A, Willer H, . 1996. Man-made mineral fibre boards in buildings- health risks caused by quality deficiencies. Toxicol Lett 88(1–3):299–303.8920752
*TIMA Inc. 1993. Man-made vitreous fibers: Nomenclature, chemical and physical properties, Stamford, CT: TIMA Inc., 1–70.
*Timbrell V. 1965. The inhalation of fibrous dusts. Ann N Y Acad Sci 132:255–273.5219552
Timbrell V. 1972. Inhalation and biological effects of asbestos. In: Mercer TT, Morrow PE, Stober W, eds. Assessment of airborne particles fundamentals, applications and implications to inhalation toxicity. Springfield, IL: Charles C Thomas, 429–445.
*Timbrell V. 1982. Deposition and retention of fibres in the human lung. Ann Occup Hyg 26(1–4):347–369.7181276
Tran CL, Jones AD, Miller BG, . 2003. Modeling the retention and clearance of manmade vitreous fibers in the rat lung. Inhal Toxicol 15:553–587.12692731
*Trethowan WN, Burge PS, Rossiter CE. 1995. Study of the respiratory health of employees in seven European plants that manufacture ceramic fibres. Occup Environ Med 52:97–104.7757174
*TRI01. 2003. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Offices of Environmental Information. U.S. Environmental Protection Agency. Toxic Release Inventory. http://www.epa.gov/triexplorer/. May 08, 2001.
Tsuda T, Morimoto Y, Yamato H, . 1997. Effects of mineral fibers on the expression of genes whose product may play a role in fiber pathogenesis. Environ Health Perspect Suppl 105(5):1173–1178.9400719
*Tsuda A, Stringer BK, Mijailovich SM, . 1999. Alveolar cell stretching in the presence of fibrous particles induces interleukin-8 responses. Am J Respir Cell Mol Biol 21:455–462.10502555
*Turim J, Brown RC. 2003. A dose-response model for refractory ceramic fibers. Inhal Toxicol 15:1103–1118.12955616
Unfried K, Roller M, Pott F, . 1997. Fiber-specific molecular features of tumors induced in rat peritoneum. Environ Health Perspect Suppl 105(5):1103–1108.9400707
*USDOC. 2002. US General exports and imports. United States Department of Commerce. USITC. 1995. Industry and trade summary. Manmade fibers. USITC Publication 2874.
Valberg PA, Blanchard JD. 1991. Pulmonary macrophage physiology: Origin, motility, endocytosis. In: Parent RA, ed. Comparative biology of the normal lung. Vol 1, Chapter 36. Boca Raton, FL: CRC Press, Inc.
*Vallarino J, Spengler JD, Buck R, . 2003. Quantifying synthetic vitreous fiber surface contamination in office buildings. Am Ind Hyg Assoc J 64:80–87.
van den Bergen EA, Rocchi PSJ, Boogaard PJ. 1994. Ceramic fibers and other respiratory hazards during the renewal of the refractory lining in a large industrial furnace. Appl Occup Environ Hyg 9(1):32–35.
Van Graft M, Spit BJ, Immel HR, . 1986. Pulmonary response of hamsters to fibrous glass. Clearance and morphology after a single intratracheal instillation. Exp Pathol 29(4):197–209.3732483
VanOrden DR. 2000. Counting rules for vitreous fiber exposures. Am Ind Hyg Assoc J 61(4):454.
*Veblin DR, Wylie AG. 1993. Mineralogy of amphiboles and 1:1 layer silicates. In: Gutherie GD, Mossman BT, eds. MSA reviews in mineralogy, Volume 28. Health effects of mineral dusts, 61–137.
*Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
Vu VT. 1994. Assessment of the potential health effects of natural and man-made fibers and their testing needs: Perspectives of the U.S. Environmental Protection Agency. In: Dungworth DL, Mauderly JL, Oberdörster G, eds. Toxic and carcinogenic effects of solid particles in the respiratory tract. Washington, DC: ILSI Press, 367–384.
Vu VT, Dearfield KL. 1993. Biological effects of fibrous materials in experimental studies and related regulatory aspects. In: Warheit D, ed. Fiber toxicology. Chapter 18. San Diego, CA: Academic Press, Inc., 449–492.
Vu VT, Lai DY. 1997. Approaches to characterizing human health risks of exposure to fibers. Environ Health Perspect 105: 1329–1336.9400747
Wagner JC, Berry G, Timbrell V. 1973. Mesotheliomata in rats after inoculation with asbestos and other materials. Br J Cancer 28(2):173–185.4354178
Walker AM, Maxim LD, Utell M. 2002. Risk analysis for mortality from respiratory tumors in a cohort of refractory ceramic fiber workers. Regul Toxicol Pharmacol 35(1):95–104.11846639
Wang Q-E, Han C-H, Wu W-D, . 1999a. Biological effects of man-made mineral fibers (1) Reactive oxygen species production and calcium homeostasis in alveolar macrophages. Ind Health 37(1):62–67.10052301
*Wang Q-E, Han C-H, Yang Y-P, . 1999b. Biological effects of man-made mineral fibers (II) Their genetic damages examined by in vitro assay. Ind Health 37(3):342–347.10441907
*Wardenbach P, Pott F, Woitowitz H-J. 2000. Differences between the classification of man-made vitreous fibers (MMVF) according to the European directive and German legislation: analysis of scientific data and implications for worker protection. Eur J Oncol 5:111–118.
Warheit DB. 1989. Interspecies comparisons of lung responses to inhaled particles and gases. CRC Crit Rev Toxicol 20:1–29.
Warheit DB, Hart GA, Hesterberg TW, . 2001. Potential pulmonary effects of man-made organic fiber (MMOF) dusts. Crit Rev Toxicol 31(6):697–736.11763480
*Wastiaux A, Blanchard O, Honnons S. 1994. Possible application of urinary analysis to estimate dissolution of some man-made vitreous fibers. Environ Health Perspect 102:217–219.
Waterman LS, Purnell CJ, Anderson PWP. 1992. Airborne fibre levels associated with the use of MMMF brazing mats during welding operations. Ann Occup Hyg 34(1):97–99.
*Watkins DK, Chiazze L, Fryar C. 1997. History cohort mortality study of a continuous filament fiberglass manufacturing plant. II. Women and minorities. J Occup Environ Med 39(6):548–555.9211213
Wedge R, Abt E, Bakshi K, . 2001. Review of the U.S. Navy’s exposure standard for manufactured vitreous fibers. Inhal Toxicol 12(1):103–108.
*Weill H, Hughes JM, Hammad YY, . 1983. Respiratory health in workers exposed to man-made vitreous fibers. Am Rev Respir Dis 128:104–112.6307098
Weiss W. 1993. Pulmonary effects of exposure to fine fibreglass: irregular opacities and small airways obstruction. Correspondence. Br J Ind Med 50:1054.8280632
Weiss W. 1996. Epidemiology of fibrous glass and lung cancer: Letter to the editor. Am J Ind Med 30:105–108.8837692
*West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
*Westerholm P, Bolander A-M. 1986. Mortality and cancer incidence in the man-made mineral fiber industry in Sweden. Scand J Work Environ Health 12 (Suppl 1):78–84.3798058
*WHO. 1985. Reference methods for measuring synthetic mineral fibers (MMMF). WHO/EURO Technical Committee for evaluating MMMF. WHO, Copenhagen.
*WHO. 1988. Man-made mineral fibers. Environmental Health Criteria. Vol. 77. Geneva: World Health Organization.
*Whong W-Z, Gao H-G, Zhou G, . 1999. Genetic alterations of cancer-related genes in glass fiber-induced transformed cells. J Toxicol Environ Health A 56(6):397–404.10096362
*Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II. The elements Part A. New York: Academic Press.
*Wilson R, Langer AM, Nolan RP. 1999. A risk assessment for exposure to glass wool. Regul Toxicol Pharmacol 30:96–109.10536105
Wong O, Musselman RP. 1994. An epidemiological and toxicological evaluation of the carcinogenicity of man-made vitreous fiber, with a consideration of coexposures. J Environ Pathol Toxicol 13(3):169–180.
*Wong O, Foliart D, Trent LS. 1991. A case-control study of lung cancer in a cohort of workers potentially exposed to slag wool fibres. Br J Ind Med 48:818–824.1772796
Woodworth CD, Mossman BT, Craighead JE. 1983. Induction of squamous metaplasia in organ cultures of hamster trachea by naturally occurring and synthetic fibers. Cancer Res 43:4906–4912.6883341
*Wright GW. 1968. Airborne fibrous glass particles. Arch Environ Health 16:175–181.5646441
*Wright GW, Kuschner M. 1977. The influence of varying lengths of glass and asbestos on tissue response in guinea pigs. Ann Occup Hyg 2:455–474.
Wu J-D, Milton DK, Hammond K, . 1999. Hierarchical cluster analysis applied to workers’ exposures in fiberglass insulation manufacturing. Ann Occup Hyg 43(1):43–55.10028893
*Wylie AG, Verkouteren JR. 2000. Amphibole asbestos from Libby, Montana: aspects of nomenclature. Am Mineral 85:1540–1542.
Xie C, Reusse A, Dai J, . 2000. TNF-α increases tracheal epithelial asbestos and fiberglass binding via a NF-kB-dependent mechanism. Am J Physiol Lung Cell Mol Physiol 2000:L608–L614.
*Xu GB, Yu CP. 1986. Effects of age on deposition of inhaled aerosols in the human lung. Aerosol Sci Technol 5:349–357.
Yamato H, Tanaka I, Higashi T, . 1992. Determinant factor for clearance of ceramic fibres from rat lungs. Br J Ind Med 49(3):182–185.1554614
Yamato H, Tanaka I, Higashi T, . 1994. Clearance of inhaled ceramic fibers from rat lungs. Environ Health Perspect 102:169–171.
Yegles M, Janson X, Dong HY, . 1995. Role of fibre characteristics on cytotoxicity and induction of anaphase/telophase aberrations in rat pleural mesothelial cells in vitro: correlations with in vivo animal findings. Carcinogenesis 16(11):2751–2758.7586195
*Yokosaki Y, Morimoto Y, Yamato H, . 1991. Cellular changes induced in rats lungs by inhalation of ceramic fibres. Toxicol Ind Health 7(5–6):479–483.1780891
*Youk AO, Marsh GM, Stone RA, . 2001. Historical cohort study of US man-made vitreous fiber production workers: III. Analysis of exposure-weighted measures of respirable fibers and formaldehyde in the nested case-control study of respiratory system cancer. J Occup Environ Med 43(9):767–778.11561360
*Yu CP, Oberdörster G. 2000. Dose-response and human cancer and non-cancer risk assessment of inhaled refractory ceramic fibers (RCF). Unpublished report to Dr. David Y. Lai. Washington, DC: U.S. Envirronmental Protection Agency.
Yu CP, Asgharian B, Yen BM. 1986. Impaction and sedimentation deposition of fibers in airways. Am Ind Hyg Assoc J 47(2):72–77.3953424
*Yu CP, Dai T, Boymel PM, . 1998a. A clearance model of man-made vitreous fibers (MMVFs) in the rat lung. Inhal Toxicol 10(4):253–274.
*Yu CP, Dai YT, Ding YJ. 1998b. A retention model of man-man vitreous fibers (MMVFs) inhaled by rats. Aerosol Sci Technol 29(2):152–162.
*Yu, CP, Ding J, Zhang L, . 1995b. Deposition and clearance modeling of inhaled kaolin refractory ceramic fibers (RCF) in hamsters- comparison between species. Inhal Toxicol 7(2):165–177.
*Yu CP, Ding YJ, Zhang L, . 1996. A clearance model of refractory ceramic fibers (RCF) in the rat lung including fiber dissolution and breakage. J Aerosol Sci 27(1):151–159.
*Yu C, Ding Y, Zhang L, . 1997. Retention modeling of refractory ceramic fibers (RCF) in humans. Regul Toxicol Pharmacol 25:18–25.9056498
*Yu CP, Zhang L, Oberdörster G, . 1994. Clearance of refractory ceramic fibers (RCF) from the rat lung: Development of a model. Environ Res 65(2):243–253.8187740
*Yu CP, Zhang L, Oberdörster G, . 1995a. Deposition of refractory ceramic fibers (RCF) in the human respiratory tract and comparison with rodent studies. Aerosol Sci Technol 23:291–300.
Zanjanian MH, Sahu A 1981. Anaphylactic reaction to fiber glass. Ann Allergy 47:157–158.7270987
*Zhong B-Z, Ong T, Whong W-Z. 1997. Studies on the relationship between treatment condition and micronucleus induction in V79 cells exposed to silica and glass fibers. Mutat Res 39:111–116.
*Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372
*Zoitos BK, DeMeringo A, Rouyer E, . 1997. In vitro measurement of fiber dissolution rate relevant to biopersistence at neutral pH: An interlaboratory round robin. Inhal Toxicol 9:525–540.
Zoller T, Zeller WJ. 2000. Production of reactive oxygen species by phagocytic cells after exposure to glass wool and stone wool fibres -effect of fibre preincubation in aqueous solution. Toxicol Lett 114:1–9.10713463
*Zoltai, T. 1979. Asbestiform and acicular mineral fragments. Ann NY Acad Sci 330:621–643.
*Zoltai T. 1981. Amphibole asbestos mineralogy. In: Veblen DR, ed. Amphiboles and other hydrous particles. MSA reviews in mineralogy. Volume 28, 235–278.